# References

Antiplatelet Trialists' Collaboration. Secondary prevention of vascular disease by prolonged antiplatelet treatment. Br Med J (Clin Res Ed). 1988;296(6618):320-31. [pmid: 3125883].
Assendelft WJ, Morton SC, Yu EI, et al. Spinal manipulative therapy for low back pain. A meta-analysis of effectiveness relative to other therapies. Ann Intern Med. 2003;138(11):871-81. [pmid: 12779297].
Ausejo M, Saenz A, Pham B, et al. The effectiveness of glucocorticoids in treating croup: meta-analysis. BMJ. 1999;319(7210):595-600. [pmid: 10473471].
Balk E, Tatsioni A, Lichtenstein A, et al. Effect of chromium supplementation on glucose metabolism and lipids: a systematic review of randomized controlled trials. Diabetes Care. 2007;30(8):2154-63. [pmid: 17519436].
Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287(22):2973-82. [pmid: 12052127].
Balk EM, Lichtenstein AH, Chung M, et al. Effects of omega-3 fatty acids on serum markers of cardiovascular disease risk: a systematic review. Atherosclerosis. 2006;189(1):19-30. [pmid: 16530201].
Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials. The CONSORT statement. JAMA. 1996;276(8):637-9. [pmid: 8773637].
Berkey CS, Hoaglin DC, Mosteller F, et al. A random-effects regression model for meta-analysis. Stat Med. 1995;14(4):395-411. [pmid: 7746979].
Bhuta T, Ohlsson A. Systematic review and meta-analysis of early postnatal dexamethasone for prevention of chronic lung disease. Arch Dis Child Fetal Neonatal Ed. 1998;79(1):F26-33. [pmid: 9797621].
Chapell R, Reston J, Snyder D. Management of Treatment-Resistant Epilepsy. May. 2003. Evidence Report/Technology Assessment No. 77. (AHRQ Publication No. 03-0028).
Colditz GA, Miller JN, Mosteller F. How study design affects outcomes in comparisons of therapy. I: Medical Stat Med. 1989;8(4):441-54. [pmid: 2727468].
Coulter I, Hardy M, Shekelle P, et al. Effect of the Supplemental Use of Antioxidants Vitamin C, Vitamin E, and Coenzyme Q10 for the Prevention and Treatment of Cancer. 2003. Evidence Report/Technology Assessment Number 75. (AHRQ Publication No. 04-E003).
Counsell C, Sandercock P. Use of anticoagulants in patients with acute ischemic stroke. Stroke. 1995;26(3):522-3. [pmid: 7533952].
Dolan-Mullen P, Ramirez G, Groff JY. A meta-analysis of randomized trials of prenatal smoking cessation interventions. Am J Obstet Gynecol. 1994;171(5):1328-34. [pmid: 7977542].
Donahue K, Gartlehner G, Jonas D, et al. Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults. November. 2007. Comparative Effectiveness Review No. 11. (AHRQ Publication No. 08-EHC004-EF.).
Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76. [pmid: 12583822].
Emerson JD, Burdick E, Hoaglin DC, et al. An empirical study of the possible relation of treatment differences to quality scores in controlled randomized clinical trials. Control Clin Trials. 1990;11(5):339-52. [pmid: 1963128].
Field AP. Meta-analysis of correlation coefficients: a Monte Carlo comparison of fixed- and random-effects methods. Psychol Methods. 2001;6(2):161-80. [pmid: 11411440].
Field AP. Is the meta-analysis of correlation coefficients accurate when population correlations vary?. Psychol Methods. 2005;10(4):444-67. [pmid: 16392999].
Furlan AD, Imamura M, Dryden T, et al. Massage for low-back pain. Cochrane Database Syst Rev. 2008;(4):CD001929. [pmid: 18843627].
Furlan AD, van Tulder M, Cherkin D, et al. Acupuncture and dry-needling for low back pain: an updated systematic review within the framework of the cochrane collaboration. Spine (Phila Pa 1976). 2005;30(8):944-63. [pmid: 15834340].
Glasziou P P, Sanders S L. Investigating causes of heterogeneity in systematic reviews. Statistics in Medicine. 2002;21(11):1503-1511. [pmid: 12111916].
Guo SY, Fraser MW. Propensity Score Analysis: Statistical Methods and Applications. 2010. Thousand Oaks, Ca. Sage.
Hagen KB, Hilde G, Jamtvedt G, et al. Bed rest for acute low back pain and sciatica. Nurs Times. 2001;97(31):40. [pmid: 11957537].
Hansen RA, Gartlehner G, Webb AP, et al. Efficacy and safety of donepezil, galantamine, and rivastigmine for the treatment of Alzheimer's disease: a systematic review and meta-analysis. Clin Interv Aging. 2008;3(2):211-25. [pmid: 18686744].
Hardy M, Coulter I, Morton SC, et al. S-Adenosyl-L-Methionine for Treatment of Depression, Osteoarthritis, and Liver Disease. October. 2002. AHRQ Evidence Report No. 64. (AHRQ Publication No. 02-E034).
Hartling L, Ospina M, Liang Y, et al. Risk of bias versus quality assessment of randomised controlled trials: cross sectional study. BMJ. 2009;339:b4012. [pmid: 19841007].
Hayden JA, van Tulder MW, Malmivaara A, et al. Exercise therapy for treatment of non-specific low back pain. Cochrane Database Syst Rev. 2005;(3):CD000335. [pmid: 16034851].
Hayes RH, Moulton LH. Cluster randomised trials. 2010. Chapman and Hall.
Hedges LV, Tipton E., Johnson M. C. Robust variance estimation in meta-regression with dependent effect size estimates. Research Synthesis Methods. 2010;1(1):39-65.
Hempel S, Suttorp MJ, Miles JNV, Wang Z, Maglione M, Morton S, Johnsen B, Valentine D, Shekelle PG. Empirical Evidence of Associations Between Trial Quality and Effect Sizes. Methods Research Report. (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-2007-10062-I). AHRQ Publication No. 11-EHC045-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: http://effectivehealthcare.ahrq.gov.
Henschke N, Ostelo RW, van Tulder MW, et al. Behavioural treatment for chronic low-back pain. Cochrane Database Syst Rev. 2010;(7):CD002014. [pmid: 20614428].
Heymans MW, van Tulder MW, Esmail R, et al. Back schools for nonspecific low back pain: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine (Phila Pa 1976). 2005;30(19):2153-63. [pmid: 16205340].
Higgins J, Green S. Cochrane handbook for systematic reviews of interventions version 5.0.2. [updated September 2009]. Cochrane Collaboration. 2008.
Higgins J, Green S. Cochrane handbook for systematic reviews of interventions version 5.1.0. [updated March 2011]. Cochrane Collaboration. 2011.
Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
Hine LK, Laird NM, Hewitt P, et al. Meta-analysis of empirical long-term antiarrhythmic therapy after myocardial infarction. JAMA. 1989;262(21):3037-40. [pmid: 2509746].
Hughes E, Collins J. P. V. WITHDRAWN: Bromocriptine for unexplained subfertility in women. Cochrane Database Syst Rev. 1996;4.
Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
Juni P, Altman DG, Egger M. Systematic reviews in health care: Assessing the quality of controlled clinical trials. BMJ. 2001;323(7303):42-6. [pmid: 11440947].
Juni P, Tallon D, Egger M. Garbage in - garbage out’? Assessment of the quality of controlled trials in meta-analyses published in leading journals. Proceedings of the 3rd symposium on systematic reviews: beyond the basics. St Catherine's College, Oxford. Oxford. Centre for Statistics in Medicine. 2000:19.
Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
Kane RL, Wang J, Garrard J. Reporting in randomized clinical trials improved after adoption of the CONSORT statement. J Clin Epidemiol. 2007;60(3):241-9. [pmid: 17292017].
Karjalainen K, Malmivaara A, van Tulder M, et al. Multidisciplinary biopsychosocial rehabilitation for subacute low back pain in working-age adults: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine (Phila Pa 1976). 2001;26(3):262-9. [pmid: 11224862].
Kellner JD, Ohlsson A, Gadomski AM, et al. Efficacy of bronchodilator therapy in bronchiolitis. A meta-analysis. Arch Pediatr Adolesc Med. 1996;150(11):1166-72. [pmid: 8904857].
Khadilkar A, Milne S, Brosseau L, et al. Transcutaneous electrical nerve stimulation (TENS) for chronic low-back pain. Cochrane Database Syst Rev. 2005;(3):CD003008. [pmid: 16034883].
Kjaergard LL, Villumsen J, Gluud C. Quality of randomised clinical trials affects estimates of intervention efficacy. Proceedings of the 7th Cochrane colloquium Universita STommaso D'Aquino. Rome Milan. Centro Cochrane Italiano. 1999:57. (poster B10).
Kjaergard LL, Villumsen J, Gluud C. Reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. 2001;135(11):982-9. [pmid: 11730399].
Kjaergard LL, Villumsen J, Gluud C. Correction: reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. 2008;149(3):219. [pmid: 18942172].
Kozyrskyj AL, Hildes-Ripstein GE, Longstaffe SE, et al. Treatment of acute otitis media with a shortened course of antibiotics: a meta-analysis. JAMA. 1998;279(21):1736-42. [pmid: 9624028].
Lau J, Antman EM, Jimenez-Silva J, et al. Cumulative meta-analysis of therapeutic trials for myocardial infarction. N Engl J Med. 1992;327(4):248-54. [pmid: 1614465].
Leizorovicz A, Boissel JP. Oral anticoagulant in patients surviving myocardial infarction. A new approach to old data. Eur J Clin Pharmacol. 1983;24(3):333-6. [pmid: 6345177].
Lensing AW, Prins MH, Davidson BL, et al. Treatment of deep venous thrombosis with low-molecular-weight heparins. A meta-analysis. Arch Intern Med. 1995;155(6):601-7. [pmid: 7887755].
Lo GH, LaValley M, McAlindon T, et al. Intra-articular hyaluronic acid in treatment of knee osteoarthritis: a meta-analysis. JAMA. 2003;290(23):3115-21. [pmid: 14679274].
Loonen AJ, Peer PG, Zwanikken GJ. Continuation and maintenance therapy with antidepressive agents. Meta-analysis of research. Pharm Weekbl Sci. 1991;13(4):167-75. [pmid: 1834986].
Loosemore TM, Chalmers TC, Dormandy JA. A meta-analysis of randomized placebo control trials in Fontaine stages III and IV peripheral occlusive arterial disease. Int Angiol. 1994;13(2):133-42. [pmid: 7525794].
Mari JJ, Streiner DL. An overview of family interventions and relapse on schizophrenia: meta-analysis of research findings. Psychol Med. 1994;24(3):565-78. [pmid: 7991739].
Marshall JK, Irvine EJ. Rectal aminosalicylate therapy for distal ulcerative colitis: a meta-analysis. Aliment Pharmacol Ther. 1995;9(3):293-300. [pmid: 7654892].
Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-13. [pmid: 9746022].
Moja LP, Telaro E, D'Amico R, et al. Assessment of methodological quality of primary studies by systematic reviews: results of the metaquality cross sectional study. BMJ. 2005;330(7499):1053. [pmid: 15817526].
Morton SC, Adams JL, Suttorp M, et al. Meta-regression Approaches: What, Why, When and How?. Agency for Healthcare Research and Quality. 2004. PMID.
Murray D. Design and analysis of group randomized trials. 1998. New York. Oxford University Press.
Pace F, Maconi G, Molteni P, et al. Meta-analysis of the effect of placebo on the outcome of medically treated reflux esophagitis. Scand J Gastroenterol. 1995;30(2):101-5. [pmid: 7732329].
Pearl J. Causality. 2nd edition. 2009. Cambridge. Cambridge University Press.
Pildal J, Hrobjartsson A, Jorgensen KJ, et al. Impact of allocation concealment on conclusions drawn from meta-analyses of randomized trials. Int J Epidemiol. 2007;36(4):847-57. [pmid: 17517809].
Ramirez-Lassepas M, Cipolle RJ. Medical treatment of transient ischemic attacks: does it influence mortality?. Stroke. 1988;19(3):397-400. [pmid: 3354028].
Roelofs PD, Deyo RA, Koes BW, et al. Nonsteroidal anti-inflammatory drugs for low back pain: an updated Cochrane review. Spine (Phila Pa 1976). 2008;33(16):1766-74. [pmid: 18580547].
Rosenbaum P, Rubin D B. The Central Role of the Propensity Score in Observational Studies for Causal Effects. Biometrika. 1983;70(1):41.55.
Rosenbaum P, Rubin DB. Reducing Bias in Observational Studies Using Subclassification on the Propensity Score. Journal of the American Statistical Association. 1984;79:516-524.
Rosenfeld RM, Post JC. Meta-analysis of antibiotics for the treatment of otitis media with effusion. Otolaryngol Head Neck Surg. 1992;106(4):378-86. [pmid: 1533027].
Rossouw JE, Lewis B, Rifkind BM. The value of lowering cholesterol after myocardial infarction. N Engl J Med. 1990;323(16):1112-9. [pmid: 2215579].
Savovic J, Harris RJ, Wood L, et al. Development of a combined database for meta-epidemiological research. Research Synthesis Methods. 2010;2(1):78.
Schroll JB, Moustgaard R, Gotzsche P. Dealing with substantial heterogeneity in Cochrane reviews. Cross-sectional study. BMC Medical Research Methodology. 2011;(11:22).
Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
Shekelle P, Hardy ML, Coulter I, et al. Effect of the supplemental use of antioxidants vitamin C, vitamin E, and coenzyme Q10 for the prevention and treatment of cancer. Evid Rep Technol Assess (Summ). 2003;(75):1-3. [pmid: 15523748].
Shekelle PG, Maglione M, Bagley S, et al. Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics. January. 2007. Comparative Effectiveness Review No. 6.
Shekelle PG, Morton SC, Maglione M, et al. Pharmacological and surgical treatment of obesity. Evid Rep Technol Assess (Summ). 2004;(103):1-6. [pmid: 15526396].
Sterne JA, Juni P, Schulz KF, et al. Statistical methods for assessing the influence of study characteristics on treatment effects in 'meta-epidemiological' research. Statistics in Medicine. 2002;21:1513-1524. [pmid: 12111917].
Sutherland LR, May GR, Shaffer EA. Sulfasalazine revisited: a meta-analysis of 5-aminosalicylic acid in the treatment of ulcerative colitis. Ann Intern Med. 1993;118(7):540-9. [pmid: 8095128].
Teo KK, Yusuf S. Role of magnesium in reducing mortality in acute myocardial infarction. A review of the evidence. Drugs. 1993;46(3):347-59. [pmid: 7693427].
Towfigh A, Romanova M, Weinreb JE, et al. Self-monitoring of blood glucose levels in patients with type 2 diabetes mellitus not taking insulin: a meta-analysis. Am J Manag Care. 2008;14(7):468-75. [pmid: 18611098].
van Duijvenbode IC, Jellema P, van Poppel MN, et al. Lumbar supports for prevention and treatment of low back pain. Cochrane Database Syst Rev. 2008;(2):CD001823. [pmid: 18425875].
van Tulder M, Furlan A, Bombardier C, et al. Updated method guidelines for systematic reviews in the cochrane collaboration back review group. Spine (Phila Pa 1976). 2003;28(12):1290-9. [pmid: 12811274].
van Tulder MW, Suttorp M, Morton S, et al. Empirical evidence of an association between internal validity and effect size in randomized controlled trials of low-back pain. Spine (Phila Pa 1976). 2009;34(16):1685-92. [pmid: 19770609].
van Tulder MW, Touray T, Furlan AD, et al. Muscle relaxants for nonspecific low back pain: a systematic review within the framework of the cochrane collaboration. Spine (Phila Pa 1976). 2003;28(17):1978-92. [pmid: 12973146].
Verhagen AP, de Vet HC, de Bie RA, et al. The art of quality assessment of RCTs included in systematic reviews. J Clin Epidemiol. 2001;54(7):651-4. [pmid: 11438404].
West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evid Rep Technol Assess (Summ). 2002;(47):1-11. [pmid: 11979732].
Wood L, Egger M, Gluud LL, et al. Empirical evidence of bias in treatment effect estimates in controlled trials with different interventions and outcomes: meta-epidemiological study. BMJ. 2008;336(7644):601-5. [pmid: 18316340].
Yusuf S, Collins R, MacMahon S, et al. Effect of intravenous nitrates on mortality in acute myocardial infarction: an overview of the randomised trials. Lancet. 1988;1(8594):1088-92. [pmid: 2896919].
Yusuf S, Collins R, Peto R, et al. Intravenous and intracoronary fibrinolytic therapy in acute myocardial infarction: overview of results on mortality, reinfarction and side-effects from 33 randomized controlled trials. Eur Heart J. 1985;6(7):556-85. [pmid: 3899654].
Yusuf S, Peto R, Lewis J, et al. Beta blockade during and after myocardial infarction: an overview of the randomized trials. Prog Cardiovasc Dis. 1985;27(5):335-71. [pmid: 2858114].