# Peer Reviewers

Ethan Balk, M.D., M.P.H.

Tufts Medical Center

Boston, MA

Nancy Berkman, Ph.D., M.L.I.R.

RTI International

Research Triangle Park, NC

Isabelle Boutron, M.D., Ph.D.

University of Oxford

Oxford, United Kingdom

Rochelle Fu, Ph.D.

Oregon Health and Science University

Portland, OR

Jonathan Sterne, Ph.D.

University of Bristol

Bristol, United Kingdom

Meera Viswanathan, Ph.D.

RTI International

Research Triangle Park, NC