# Methods

## Quality Criteria

We applied the CBRG Internal Validity criteria (van Tulder et al, 2003) to individual trials included in a dataset. In addition, we used the Jadad scale (Jadad et al., 1996), criteria proposed by Schulz et al. (1995), and the Cochrane Risk of Bias tool (Higgins & Green, 2008). The items and the scoring guideline are shown in the appendix. The criteria address the internal validity of the trials, design and execution factors, and the adequacy of the reporting of the trial.

### CBRG Internal Validity Criteria

We applied the 11 CBRG Internal Validity criteria (van Tulder et al., 2003) that appeared very promising in the quality scoring of Cochrane back reviews. The individual criteria address the adequacy of the randomization sequence generation, concealment of treatment allocation, baseline similarity of treatment groups, outcome assessor blinding, care provider blinding, patient blinding, adequacy and description of the dropout rate, analysis according to originally assigned group (intention-to-treat [ITT] analysis), similarity of co-interventions, adequacy of compliance, and similar assessment timing across groups.

The items are scored ‘Yes,’ ‘No,’ and ‘Unclear.’ There is guidance for the appropriateness of each answer category (see appendix for the full scoring instructions). For example, assessor blinding is scored positively when assessors were either explicitly blinded or the assessor is clearly not aware of the treatment allocation (e.g., in automated test result analysis). A number of items are typically defined according to the clinical field, that is, in order to select the most relevant variable to adequately judge baseline comparability or to determine thresholds for dropouts that are adequate for the individual clinical field.

### Jadad Scale

In addition, we applied the Jadad scale (Jadad et al., 1996) as one established measure of study quality. Use of this scale entails the assessment of the presence and quality of the randomization procedure (0 to 2 points), the presence and quality of double-blinding procedure (0 to 2 points), and the description of withdrawals (0 to 1 point). The items are summed, with summary scores varying from 0 to 5.

### Schulz’s Criteria

For comparison reasons, we also used criteria proposed by Schulz et al. (1995), operationalized as in the original publications. Schulz introduced the assessment of the concealment of treatment allocation, a dimension that showed the most consistent differences in high- and low-quality studies in previous analyses. In addition, the generation of the allocation sequence, the inclusion in the analysis of all randomized participants, and the reporting of double blinding are scored as present or not.

### Cochrane Risk of Bias Tool

Finally, we also applied the Cochrane Risk of Bias tool, a widely used tool to assess RCTs published in the 2008 version of the Cochrane Handbook for Systematic Reviews of Interventions (Higgins & Green, 2008). The quality features that were assessed were whether the allocation sequence was adequately generated, whether the allocation was adequately concealed, whether knowledge of the allocated treatment was adequately prevented during the study (blinding), whether incomplete outcome data were adequately addressed, whether the reports of the study are free of suggestion of selective outcome reporting, and whether the study was apparently free of other problems that could put it at a high risk of bias. Finally, the reviewers assessed the overall risk of bias of each study, expressed as high, low, or unclear. The Cochrane Risk of Bias Tool has since been revised and now distinguishes assessor blinding from blinding of participants and personnel (Higgins & Gree, 2011).

The table below (Table 1) shows the quality domains that are represented in the different critical appraisal instruments that were applied in parallel. The individual interpretation of the quality domains, that is the operationalization and scoring instructions, vary across instruments and are shown in full in the appendix. Some translations address the reporting of the trial details, the design and execution factors, or both.

Table 1 Represented quality domains

Quality Domain | CBRG | Jadad | Schulz | RoB
Randomization | x | x | x | x
Allocation concealment | x | | x | x
Similar baseline | x
Assessor blinding | x
Care provider blinding | x
Patient blinding | x
Dropouts and withdrawals | x | x
Original group (ITT) | x
Similar co-interventions | x
Acceptable compliance | x
Similar timing | x
Blinding (summary item) | | x | x | x
Analysis of all pts / exclusions | | | x
Incomplete outcome data | | | | x
Selective outcome reporting | | | | x
Other sources of bias (undefined) | | | | x
Quantitative summary score | x | x
Overall risk of bias assessment | | | | x

CBRG = Cochrane Back Review Group; RoB = risk of bias; ITT = intention to treat

Note: The individual operationalizations and scoring instructions vary across instruments.

Several domains relate to the potential for selection bias (randomization, allocation concealment, similar baseline for treatment and control group), the potential for performance and detection bias (assessor blinding, patient blinding, care provider blinding or summary blinding judgment; similar co-interventions, similar timing of the outcome assessment in treatment and control groups), the potential for attrition bias (description, rate, and handling of dropouts and withdrawals, analyses of participants according to randomization / intention-to-treat analysis, exclusion from the analyses, incomplete outcome data), and unique dimensions (compliance, selective outcome reporting, other (undefined) sources of bias), or summary assessments (quantitative or qualitative).

In comparison, the CBRG criteria cover all general dimensions assessed by the other three measures apart from the selective outcome reporting in addition to unique dimensions (e.g., similar timing of outcome assessments). However, individual interpretations and scoring instructions vary across the instruments.

## Study Pool Selection

This project drew on empirical study pools as well as Monte Carlo simulations to estimate effects.

We used four epidemiological datasets to investigate the research questions. The four datasets consisted of up to 12 meta-analyses each, and each meta-analysis included a varying number of individual trials ranging from 3 to 45 trials. There were no overlaps in included trials across datasets. Three datasets have been described in detail in previous work; one new dataset was added for the purpose of this report. Two datasets were available to us through previous work, two other datasets were assembled for their “known characteristics” with regard to associations between quality and effect sizes as outlined in detail below.

### Dataset 1 Back Pain Trials

RCTs in this dataset were included in reviews of non-surgical treatment for non-specific low-back pain present in the Cochrane Library 2005, issue 3 (Assendelft, Morton, Yu, et al. 2004; Furlan, van Tulder, Tsukayama, et al., 2005; Furlan, Imamura, Dryden, et al., 2008; Hagen, Hilde, Jamtvedt et al., 2001; Hayden, van Tulder, Malmivaara, et al. 2005; Henschke, Ostelo, van Tulder, et al., 2005; Heymans, van Tulder, Esmail, et al., 2005; Karjalainen, Malmivaara, van Tulder, et al., 2001; Khadilkar, Odebiyi, Brosseau, et al., 2005; Roelofs, Deyo, Koes, et al., 2005; van Tulder, Touray, Furlan, et al., 2003; van Duijvenbode, Jellema, van Poppel et al., 2005). The reviews from eight topic areas assessed the effects of acupuncture, back schools, behavioral therapy, exercise therapy, spinal manipulative therapy, muscle relaxants, non-steroidal anti-inflammatory drugs (NSAIDs), and other approaches (bed rest, lumbar supports, massage, multidisciplinary bio-psycho-social rehabilitation, and transcutaneous electrical nerve stimulation) for the treatment of low-back pain. Comparisons were placebo, usual care, no treatment, or other treatments. The dataset included 216 trials. This dataset is described in detail elsewhere (van Tulder et al., 2009).

### Dataset 2 EPC Reports

This dataset was assembled for a previous methods report on associations between quality and effect sizes (Hempel et al., 2011) and is based on Evidence-based Practice Center (EPC) reports. We searched prior systematic reviews and meta-analyses conducted by AHRQ-funded EPCs with the goal of assembling a dataset of trials that represented a wide range of clinical topics and interventions. As outlined in the report, the criteria for selection were that the EPC report had to include a meta-analysis and that the EPC had to be willing to provide us with the data on outcomes, such that we needed only assess the quality of the included trials. The dataset was drawn from 12 evidence reports, the majority of which were also published as peer review journal articles (Balk, Lichtenstein, Chung, et al., 2006; Balk, Tatsioni, Lichtenstein, et al., 2007; Chapell, Reston, Snyder, et al., 2003; Coulter, Hardy, Shekelle, et al., 2003; Donahue, Gartlehner, Jonas, et al., 2007; Hansen, Gartlehner, Webb, et al., 2008; Hardy, Coulter, Morton, et al., 2002; Lo, LaValley, McAlindon, et al., 2003; Shekelle, Morton, Hardy, 2003; Shekelle, Maglione, Bagley, et al., 2007; Shekelle, Morton, Maglione, et al., 2004; Towfigh, Romanova, Weinreb, et al., 2008). The reports addressed diverse topics, and included pharmacological therapies as well as behavior modification interventions. All trials included in the main meta-analysis of the report were selected; studies included in more than one report entered our analysis only once. The dataset included 165 trials.

### Dataset 3 “Pro-bias” set

This third dataset was obtained by replicating a selection of trials used by Moher et al. (1998). The dataset was chosen because it has shown evidence of bias for established quality criteria (see Moher et al., 1998) and is, therefore, designated in this report as “pro-bias.” We replicated the methods described by Moher et al. for selection of trials. Two reviewers independently reviewed the 11 meta-analyses chosen by the authors. These meta-analyses covered digestive diseases (Marshall & Irvine, 1995; Pace, Maconi, Molteni, et al., 1995; Sutherland, May,and Shaffer, 1993), circulatory diseases (Ramirez-Lasspas and Cipolle, 1988; Lensing, Prins, Davidson, et al., 1995; Loosemore, Chalmers, and Dormandy, 1994), mental health (Mari and Streiner, 1994; Loonen, Peer and Zwanikken, 1991; Dolan-Mullen, Ramirez, and Groff, 1994), stroke (Counsell and Sandercock, 1995), and pregnancy and childbirth (Hughes, Collins, and Vanderkeckhove, 1996). We were able to retrieve, quality score, and abstract 100 RCTs of the originally published dataset (79 percent).

### Dataset 4 “Heterogeneity” set

For the purpose of this report, we compiled a fourth dataset of meta-analyses and included trials. This dataset was obtained by replicating a selection used by Balk et al. (2002). The dataset was chosen because heterogeneity across studies was one of the inclusion criteria to select meta-analyses for the dataset. In addition, the “known quality” for this dataset was its demonstrated lack of reliable association between quality and effect sizes across studies and quality criteria. For this dataset meta-analyses were included that demonstrated significant heterogeneity in the odds ratio scale defined as p<0.10 for the chi-square statistic of between-study heterogeneity or a nonzero variance tau-squared (τ^2^) in DerSimonian and Laird random-effects models. We selected the eight included cardiovascular disease meta-analyses and the five pediatric meta-analyses from this dataset. Since the original publication does not specify exactly which trials were included in the analysis, we replicated the methods described by Balk et al. (2002) for trial selection.

The cardiovascular disease trials were derived from published meta-analyses on treatment with aspirin (Antiplatelet Trialists’ Collaboration, 1988), Class I antiarhythmics (Hine et al., 1989), anticoagulants (Leizorovicz and Boissel, 1983), beta-blockers (Yusuf et al., 1985), intravenous streptokinase (Yusuf et al., 1985), nitrates (Yusuf et al., 1988), cholesterol reduction agents (Rossouw et al., 1990), and magnesium (Teo and Yusuf, 1993), and an update search published by Lau et al. (1992). The pediatrics meta-analyses investigated glucocorticoids (Ausejo et al., 1999), dexamethasone (Bhuta and Ohlsson, 1998), bronchodilators (Kellner et al., 1996) , short-course antibiotics (Kozyrskyj et al., 1998), or antibiotics (Rosenfeld & Post, 1992). The individual trials reported on the outcome mortality, improved croup score, chronic lung disease, unimproved bronchiolitis distress score, acute otitis media failure to cure, and otitis media with effusion failure to cure. Our replication of these two clinical topics includes 149 trials; Balk et al. (2002) included 153 trials. The references of the included trials are shown in the appendix.

The flow diagram (Figure 2) summarizes the dataset composition.

Figure 2 Flow diagram

CBRG = Cochrane Back Review Group; EPC = Evidence Based Practice Center

Figure 2 is a flow diagram that summarizes the composition of the four datasets described in the text. Displayed are the names of the datasets, the eligible reviews and meta-analyses, the eligible trials, and the number of trials. Each dataset is described in detail in the Empirical Datasets section.

## Procedure

For all datasets, two reviewers independently rated each trial by applying the outlined criteria. For dataset 1 we used the published quality scores from the individual Cochrane reviews. For dataset 2 to 4 the majority of trials were rated by the same set of reviewers. We developed and pilot tested a standardized form to record decisions for the quality and risk of bias criteria. The reviewers used the full publications to score the studies and were not blinded to the identities of authors, journals, or other variables. The reviewers were experienced in critical appraisal of research studies in the context of evidence-based medicine and underwent an additional training session for this study. The pair of reviewers reconciled any disagreement through consensus; any remaining disagreements were resolved by discussion in the research team.

The outcomes of the individual RCTs were extracted by a statistician, together with measures of dispersion, where available, and the number of participants in each treatment group. The selected outcome per trial was determined by the meta-analyses the trial was part of. The outcome was either the primary outcome, or the outcome in a meta-analysis that included the largest number of trials, where more than one meta-analysis was presented and trials reported more than one outcome.

Most trials were compared against placebo. In trials with active comparisons, the coining of treatment and control group (that is the decision which group was considered the intervention and which the control group for the analysis) was either guided by input from experts in the research field or applied the selection made in the original meta-epidemiological dataset (two of the utilized datasets are replications of previously reported datasets). Sensitivity analyses such as restricting to data from placebo-controlled only studies did not indicate effects of the coining or the use of absolute effect sizes on associations between quality and effect sizes. However, for dataset 1 (Back pain) absolute effect sizes were selected as the final measure because this dataset included more comparisons between treatment and placebo as well as comparisons between active treatments than the other datasets.

For dataset 1 (Back pain) and 2 (EPC reports), in order to be able to combine studies within datasets or potentially between datasets, standardized effect sizes (ES) were computed for each study. As all studies in dataset 3 (Pro-bias) and dataset 4 (Heterogeneity set) reported dichotomous outcomes, odds-ratios were calculated. As a quality check, the point estimate and 95 percent confidence interval (CI) of each meta-analysis included in each dataset was calculated and compared to the original meta-analytic result. To explore effects of coining in dataset 4, we calculated ratios of odds ratios separately for studies favoring the treatment group in a sensitivity analysis.

The Monte Carlo simulations and the effect size distribution analyses are based on datasets 1 to 3. Dataset 4 was compiled in parallel to this work and was primarily used to replicate associations between quality and effect sizes in a dataset that had been selected in parts based on the presence of heterogeneity in meta-analyses.

## Analysis

### Association Between Quality and Effect Sizes in Empirical Datasets

We investigated the association between quality and effect sizes in two ways. First, the differences between results in studies that met a quality criterion and those that did not were calculated for each quality feature. Secondly, we used a quantitative summary score and explored different cut-offs of quality scores according to the number of quality criteria met.

For all analyses, we differentiated quality items scored “yes” and those with the quality item scored “not yes,” which included the answers “no” and “unclear.”

Trials in two of the datasets used a continuous outcome, and two used a dichotomous outcome. For continuous outcomes we used the difference in effect sizes between two subgroups (studies with criterion met versus studies that did not meet the quality criterion) as a measure of bias. The difference was estimated using meta-regression (Berkey et al., 1995). A random effects meta-regression was conducted separately for each quality criterion. The coefficient from each regression estimates the difference in effect sizes between those studies with the quality feature scored “yes” (criterion met) versus “not yes” (criterion not met or unclear). No effect of quality would be shown as identical effect sizes between high- and low-quality trials, that is effect sizes would be independent from meeting or not meeting quality criteria. A difference with a significance level of p<0.05 was considered statistically significant.

In two other datasets (set 3 and 4), all studies used dichotomous outcomes. An odds ratio below 1 indicated the treatment group is doing better than the control group. For the analysis, we compared odds ratios (OR) of studies where the quality criterion was either met or not met and computed the ratio of the odds ratios (ROR). The ROR is OR(no)/OR(yes) where OR(no) is the pooled estimate of studies not meeting the quality criterion and OR(yes) is the pooled estimate of studies where the quality criterion is met.

We also aggregated across CBRG criteria and computed quantitative summary scores based on the number of criteria met. Different cut-offs (depending on the number of criteria met) were explored to differentiate high and low quality studies. The difference in effect sizes and ratios of odds ratios of studies above and below possible thresholds was investigated.

All meta-epidemiological datasets used in this project consisted of trials that were selected through meta-analyses. These meta-analyses then contributed individual trials that make up the total dataset. Different statistical techniques have been suggested to investigate the effects of study characteristics such as the quality of individual trials and approaches vary regarding the integration of the clustering (e.g., Sterne et al., 2002). We investigated the effects of clustering by contrasting the corrected and uncorrected associations between quality and effect sizes. Meta-regressions correcting for clustering with meta-analysis were analyzed using a Huber/White (sandwich) estimator (Hedges et al., 2010).

### Heterogeneity and Effect Size Distributions

As outlined, for the purpose of this report we assembled one dataset based on a published meta-epidemiological dataset that was specifically designed to represent heterogeneity between trials. One of the selection criteria for the trials that were included in this dataset was that meta-analyses used to establish the dataset had to report evidence of heterogeneity across trials (see Balk et al., 2002). Heterogeneity in meta-analysis refers to the variance in the estimated effect sizes between studies. In a fixed-effects meta-analysis, it is assumed that all studies are sampled from the same population, and hence variation in e sizes is due only to random variation. The degree to which the effect size in each study varies from the estimated population effect size is a function of the sample size of that study. Larger studies would be expected to have point estimates of effect size which are closer to the pooled estimate than smaller studies. Thus if the fixed-effects assumption is true, a meta-analysis containing studies with smaller sample sizes would have greater variance in effect sizes than a meta-analysis containing larger sample sizes.

Heterogeneity in meta-analysis is quantified using several measures. Q is a test statistic which assesses the total variance of the effect sizes of the studies. When the fixed-effects assumption is true, the expected value of Q is approximately equal to the number of studies minus one. The value of the statistical significance of Q depends on the number of studies, hence interpretation is difficult. An alternative to Q is I^2^. I^2^ is calculated as: 100 ( Q − ( r − 1 ) ) / Q , where r is the number of studies included in the meta-analysis. I^2^ is the proportion of variance in the effect sizes that cannot be explained by chance. I^2^ values close to zero indicate little or no heterogeneity, whereas those closer to 100 percent indicate higher levels of heterogeneity (Higgins, Thompson, Deeks, and Altman, 2003). Values of I^2^ of 25 percent are considered small, 50 percent are considered moderate, and 75 percent are considered large. When Q is lower than r-1, values of I^2^ below zero are possible. However, when this is the case, I^2^ is bounded at zero, and is constrained to be zero.

The datasets comprise different meta-analyses that each contain individual trials. In the empirical datasets we used I^2^ to measure the percent of variation across trials in each meta-analysis that is due to heterogeneity. In addition, we computed I^2^ across all trials at the dataset level regardless of the meta-analyses the trial was originally part of as an estimate of the variation represented by the datasets.

#### Effect Size Distribution

In our previous report (Hempel et al., 2011), we discussed our observation that the three different datasets used to investigate associations between quality and effect sizes varied in a number of characteristics. In particular, the dataset distributions of both effect sizes and quality scores of the included trials varied considerably across analyzed datasets. Compared to the other datasets, dataset 1 (Back pain data, van Tulder et al., 2009) was more symmetric, and this dataset also showed consistent quality-effect size associations. In contrast, dataset 2 showed a noticeable skewed distribution of reported effect sizes and incidentally also no association between quality scores and effect sizes. The variation in effect sizes alone may explain the differential associations between quality and effect sizes observed across datasets. In order to address the variation, we aimed to sample datasets to mirror distributions found in the various analyzed datasets in an exploratory analyses.

First, we manually sampled effect sizes from dataset 1 in an attempt to replicate the distribution of effect sizes seen in dataset 2. However, the inspection of the resulting distributions showed that we were not able to match the shape of the distributions satisfactorily. Instead, we used a non-parametric approach in order to mirror the various distributions. First we ranked the trials included in dataset 1 and dataset 2 from the smallest to the largest effect size. Then we matched the rankings and assigned dataset 2 effect sizes to the dataset 1 quality criteria based on the rankings of the effect sizes within the datasets. Hence the quality scoring was kept the same from one dataset and we sought to find out what the associations between quality and effect sizes would be if the effect sizes and the resulting distribution were those of the second dataset.

Since the datasets varied in size, we sampled from the largest dataset (without replacement) to get to the number of studies in the smallest dataset. Hence, we sampled 165 studies from dataset 1 to map to the 165 in dataset 2. For dataset 3, we sampled 100 dataset 2 studies to map to the data.

The treatment effects are expressed as effect sizes in dataset 1 and 2 but as odds ratios in dataset 3, as dataset 3 included trials reporting on categorical outcomes. Thus, for dataset 3 (“Pro-bias”), we computed the ratio of odds ratios between high and low quality trials.

### Monte Carlo Simulations

We created datasets by Monte Carlo simulation methods to systematically explore the effect of factors that influence the ability to detect the association between quality and effect sizes in meta-epidemiological datasets. We investigated the effect of sample size, heterogeneity, and the size of the quality effect operationalized as a difference in effect sizes between low and high quality studies. We determined the properties of the sampling distribution of the meta-regression estimates under different conditions to determine the factors that influence the likelihood of detecting associations between quality and effect sizes.

Meta-analyses combine the results of multiple studies testing the same hypothesis and estimate a pooled effect. The reported effect sizes are estimates of the true (population) treatment effect. Effect sizes across individual studies may show variation. As outlined, study quality has been found to influence effect sizes in a number of meta-epidemiological studies (but not all) using datasets consisting of a number of meta-analyses and their included trials. Typically, lower quality studies are being associated with larger effect sizes. In a meta-analysis, failure to account for study quality may lead to additional heterogeneity and bias in the parameter estimates. However, not all meta-epidemiological studies or individual meta-analyses find an association between quality and effect sizes. The circumstances under which quality is associated with bias (a deviation from the true treatment effect) are largely unknown.

The power of a statistical test of a null hypothesis is the probability that the null hypothesis will be rejected – that is, that the test is statistically significant – given certain population parameters, and a sample size for that study. For many statistical tests, it is relatively straightforward to estimate the power of the test: For example, for a t-test comparing the means of two samples with equal variance, knowing the size of the sample, the standardized difference between the means (in the population), and the value to be used as a cut-off for alpha (almost always 0.05), we can estimate the probability that the null hypothesis will be rejected. For more complex statistical tests the distributional characteristics of the test statistics are not necessarily known and hence power cannot be calculated.

We undertook Monte Carlo simulations to determine the power of the meta-regressions in datasets to detect quality effects, given different levels of quality effects and sample sizes. In a first step, we investigated the power and average parameter estimates for different models in Monte Carlo simulations, e.g., in models where quality was not considered compared to models where quality was added to the model. In these basic models, we also investigated moderator effects such as the size of the treatment effect. The basic models assumed an arbitrary number of trials per meta-analysis and participants per treatment. However, the final results presented in this report are based on models that correspond to existing empirical datasets to increase their external validity. Three datasets were used (Back pain, EPC reports, Pro-bias), all described in detail elsewhere (Hempel et al., 2011).

#### Design

We used Monte Carlo simulation to examine the effects of heterogeneity on the ability of meta-analyses to detect quality effects in datasets that correspond to existing empirical meta-epidemiological datasets. We generated data sampled from populations that matched three meta-epidemiological datasets in terms of number of trials, sample size per trial and level of heterogeneity in the overall dataset. We then randomly assigned 50 percent of trials to be high quality and 50 percent to be low quality. Use of 50 percent maximizes the power to detect quality effects. In fact, the proportion of high-quality studies varied across the datasets and between measures of quality; however the effects of variation in the proportion of categorical predictor variables are well known, hence we did not investigate this factor. Given that the additional structure of trials being included in about one dozen meta-analyses per dataset had only a negligible effect on the associations between quality and effect sizes, the additional structure was not added to the simulation model and for each dataset only the number of trials, not the specific number of meta-analyses, was integrated into the model.

The simulations proceeded in the following manner. First, we generated a vector of effect sizes (d_j_) for each trial. Trials were randomly assigned to be high quality or low quality. For high quality trials, B = 0, for low quality trials, B > 0, indicating a larger effect size for lower quality trials. Then for J trials sampled from a normal distribution with mean of D and variance ν.

d_j_ ~ N ( D + Q_j_ , ν )

The second stage was to generate individual trial participant data (y_ij_) for n_j_ participants within each trial, by multiplying the treatment effect for that trial (d_j_) by the condition of the individual in that trial (x_ij_), giving a value of either 0 or d_j_, the individual participant value was then sampled from a normal distribution with mean equal to either 0 or d_j_.

y_i j_ ~ N ( d_j_ , x_i j_ , 1 )

Thus:

y_i j_ = ( d_j_ + L_J_ B + ζ_j_ ) x_i j_ + ε_i j_

Where:

y_ij_ is the outcome variable for individual i in study j.

d_j_ is the effect size for high quality studies.

L_J_ is a dichotomous (0, 1) indicator of low study quality.

B is the increase in effect size associated with a low quality study.

ζ_j_ is the random heterogeneity parameter, with standard deviation equal to ν.

x_ij_ is a dichotomous individual level indicator of intervention group status (0, 1).

ɛ_ij_ is a random error term, with standard deviation equal to 1.

When the data had been generated, we calculated the mean and standard deviation of the intervention and control groups for each study.

For each of the three datasets we systematically altered two parameters: First, we generated populations with quality effects (B) of 0.1 and 0.2 (on the standardized effect scale), reflecting the approximate range of the quality effects within the datasets. Outcome data were generated for individual trial participants for intervention (x = 1) and control (x = 0) groups for each trial, with 50 percent of individuals assigned to each group.

We modeled heterogeneity by adding a variance parameter (ν) to the simulations—each meta-analysis was comprised of studies sampled from a population with a specified effect size (d), effect sizes were generated at the study level, and then (for heterogeneity) a random parameter was added to the effect size, to introduce population level heterogeneity. We used a value for ν such that the τ^2^ from the simulation matched the τ^2^ for the sample. To model reduced heterogeneity we halved the value of the parameter that was added.

To explore the effects of heterogeneity, we ran simulations with three separate values for the heterogeneity parameter: First, with a heterogeneity parameter that gave a value for τ^2^ that matched the dataset; second we halved the value of the variance parameter, and third we used a heterogeneity parameter of zero (i.e. no heterogeneity at the population level). This gave 3 (levels of heterogeneity) × 2 (quality effects) = 6 cells in the simulation for each dataset. For each of these cells in the simulation we generated and analyzed 1000 datasets.

A function was written in R version 2.12 (R Development Core Team, 2010) to generate data, analyze simulations, and aggregate results. The R code is shown in the appendix (See Description of Monte Carlo Simulation). Random effects normally distributed with a mean of 0 were simulated via the rnorm() function. The effect size for each study was calculated using the es() function in the metafor package (version 1.5; Viechtbauer, 2010), and the results were then pooled using the rma() function of the metafor package, using the DerSimonian-Laird random effects estimator.