# Introduction

## Background and Scope

For evidence syntheses that systematic reviews provide, the critical appraisal of studies is an important process. The quality of the evidence and the potential for bias in reported results should be taken into account when evaluating individual studies or the overall existing evidence base. Variation in the quality of studies may also explain differences in individual study results across studies. The quality of studies is routinely assessed in meta-analyses as a potential source of heterogeneity; that is, variation in study results across different studies. For researchers preparing overviews and policy makers utilizing these evidence overviews, it is important to know which features, if any, are most likely to distort study results. However, associations between study quality and effect sizes are complex, empirical evidence of bias has been established only for selected quality criteria, and open questions regarding the presence and detection of bias should be explored further.

A large number of individual quality criteria and quality checklists or scales have been proposed for controlled trials (see e.g. Moja, Telaro D’Amico, et al. 2005; West, King, Carey, et al., 2002). These tools cover primarily potential threats to the internal validity of the trial methodology. Juni et al. (2001) differentiate dimensions related to selection bias (e.g. inadequate randomization), to performance and detection bias (e.g. outcome assessors not blind to the intervention allocation), and to attrition bias (e.g., deviations from the randomization protocol and analysis exclusions). The assessment of the methodological quality of a trial is closely linked to the quality of the reporting. Typically, only the information reported in the publication on the trial is available to the reader to judge the quality of the trial. Quality can also relate to the external validity of studies which refers to the generalizability of study results; quality is undoubtedly a multidimensional concept (Juni et al., 2001), definitions vary, and there is little consensus on its scope.

Quality checklists typically provide a selection of quality features that are scored individually. In addition, quality scales provide a total quality score, a quantitative summary score derived from the individual criteria either by summing up individual features (giving equal weights to each feature) or by putting more emphasis on selected features. Existing quality checklists and scales address primarily the conduct of the individual study or its research methodology and concern the internal validity of the research study, but frequently include also other quality aspects such as the quality of the reporting of trial evaluation. Jadad and colleagues (Jadad, Moore, Carroll et al., 1996) proposed a scale of 0 to 5 to evaluate RCTs with low and high internal validity in pain research. The Jadad scale, based on three criteria (randomization, double-blinding, and a description of dropouts), is widely used as a summary quality measure of RCTs. A central criterion, the concealment of treatment allocation, was introduced by Schulz et al. (1995) and is widely used in addition to the criteria proposed by Jadad et al. (1996).

Design and execution factors of randomized controlled trials (RCTs) are widely believed to be associated with the treatment effects reported for those studies. This association is an indicator of bias. We define bias as a systematic deviation of an estimate, in this case the deviation of the estimated treatment effect from the true value. More factors have been proposed to be related to bias than have actually been confirmed by systematic examination of associations between quality and reported treatment effects. When assessing the quality of trials it is assumed that the conduct of the research methodology may influence the result that is obtained by the trial. The study methodology appears to distort the true value expected to be shown in the study. There is evidence for some methodological variables showing that low quality trials exaggerate treatment effects. Colditz, Miller, and Mosteller (1989) found RCTs to have smaller effect sizes than non-RCTs in trials of surgical therapy, and RCTs that were double-blind had smaller effect sizes than non-blinded trials of medical therapy. Schulz, Chalmers, Hayes et al. (1995) reported that inadequate concealment of allocation accounted for a substantial increase in effect sizes. The lack of double blinding was also shown to be associated with an increase in reported treatment effect. Moher, Pham, Jones, et al. (1998) used Jadad’s scale and Schulz’s “concealment of allocation” in a large study that assessed 11 meta-analyses (including 127 RCTs). All trials were scored and the meta-analyses replicated. Low-quality trials were associated with an increased treatment estimate compared with high-quality trials. Studies with inadequate treatment allocation concealment also showed an increased effect size compared to concealed trials. Juni, Altman, and Egger (2001) have summarized the data from Schulz et al. (1995), Moher et al. (1998), Kjaergard, Villumsen, and Gluud (1999) and Juni, Tallon, Egger, et al. (2000) in a pooled analysis, and provide evidence for associations of effect sizes with allocation concealment and double blinding, whereas the generation of treatment allocation did not show a statistically significant effect across datasets. Allocation concealment may show the most consistent associations with effect sizes (Hempel et al., 2011; Kjaergard, Villumsen, & Gluud, 2008).

The quality of individual trials is of particular importance to systematic reviews. Reviews that aim to summarize the available evidence adequately are particularly affected by results that depend on the quality of the trial. The methodological quality of studies included in a systematic review can have a substantial impact on treatment effect estimates (Verhagen, de Vet, de Bie, Boers, & van den Brandt, 2001). Pildal, Hrobjartsson, Jorgensen, et al. (2007) outline the potential consequences for meta-analysis conclusions. When only trials with adequate concealment were included in meta-analyses, two-thirds lost statistical significance of the primary result, primarily due to loss of power (as a result of a smaller sample size) but also due to a shift in the point estimate towards a less beneficial effect. These studies provide data on quantifying the risk of bias associated with individual or sets of quality criteria.

The 2008 Cochrane Handbook (Higgins and Green, 2008) introduced a Risk of Bias tool that suggested the assessment of the randomization sequence generation, the concealment of treatment allocation, blinding, the adequate handling of incomplete outcome data, selective outcome reporting, and other sources of bias. These criteria were selected based on the existing evidence for bias; that is, an association between quality criteria and effect sizes, and the tool is much more comprehensive than many existing quality checklists. The tool also refrains from using a quantitative summary score approach for an overall assessment of the risk of bias of the study and suggests that reviewers take the individual quality domains into account and use their judgment to decide which domains are crucial for the evaluation. However, the inter-rater reliability of these judgments may be limited (Hartling et al., 2009). Furthermore, the tool explicitly put more emphasis on individual outcomes and suggested that the potential for bias should be assessed for each individual outcome rather than assessing the study’s overall quality or overall risk of bias.

The Cochrane Back Review Group (CBRG) Editorial Board developed an 11-item criteria list in an expert-guided process for the assessment of trials included in Cochrane reviews by the group. The items cover established quality criteria (allocation concealment, blinding) as well as criteria for which the potential for bias has rarely been investigated or existing investigations showed conflicting results (e.g., similarity of co-interventions, compliance). The tool addresses aspects of internal validity of trials as well as the quality of the reporting. These quality criteria showed consistent influences on effect sizes of trials reporting interventions for back pain (van Tulder, Suttorp, Morton, et al., 2009). In addition, a quantitative summary score of 0 to 11, based on the 11-item list, was applied as a measure of overall internal validity. A cut-off of 5 or 6 criteria met (out of 11) differentiated high and low quality trials best (that is showing the largest difference in effect sizes between high- and low-quality studies). When applying the criteria to other datasets, we found mixed results (Hempel et al., 2011). Associations between individual as well as sum scores were found in one out of two additional datasets of interventions covering a wide range of clinical areas.

### Presence and Detection of Associations Between Quality and Effect Sizes

The variation in associations between quality and reported effect sizes across datasets raises several questions. In our analyses, we found that in one meta-epidemiological dataset the extended list quality criteria (CBRG quality criteria set) did not appear to be useful in differentiating high and low quality studies, meaning that effect sizes were not consistently higher in studies not meeting quality criteria across the CBRG criteria compared with studies meeting the criteria. However, in this same dataset, even well established individual criteria such as blinding, as well as summary scores such as the Jadad score or the CBRG summary score, showed no associations with effect sizes. The dataset included meta-analyses of EPC reports covering a wide range of clinical fields (Hempel et al., 2011). From this result it can be concluded that either the CBRG criteria did not apply to the trials present in the dataset or that other factors inherent in the dataset influenced either the presence or the detection of associations between quality and effect sizes. Similarly, Emerson, Burdick, Hoaglin, et al. (1990) found no relationship between a consensus-developed quality scale (0 to 100 points) and treatment effect differences. Balk, Bonis, Moskowitz, et al. (2002) applied 24 existing quality measures and assessed a number of meta-analyses involving 276 RCTs. The study found no indication of bias; individual quality measures were not reliably associated with the strength of treatment effect across studies and clinical areas.

The association between quality features and effect sizes may vary across datasets according to factors yet to be explored. Investigating moderators and confounders that may influence the association between quality and effect sizes (or its detection) and that may explain some of the conflicting results shown in the literature, is a new and evolving field. The following two paragraphs outline factors that have been discussed in the literature and that may influence the shown association between quality and effect sizes in meta-analyses and meta-epidemiological datasets.

Among other factors, it has to be taken into account that critical appraisal in systematic reviews is based on reported information. The information reported depends on the information authors choose to report, which is likely influenced by the word limits that many journals impose, which may make it impossible for authors to fully explain the trial methodology. Reported characteristics depend to some extend on the convention at the time of publishing and journal requirements. The publication of the Consort Statement (Begg et al., 1996) provides much-needed guidance for authors to enable them to standardize and improve the reporting of RCTs.

Another factor to consider is that not much is known about the reliability of the assessment process. Few tools have been psychometrically evaluated. The Jadad scale is one of the few tools with known inter-rater reliability (Jadad et al., 1996). Recently, the Cochrane Risk of Bias tool has been evaluated (Hartling et al., 2009), and the results indicate that more guidance is needed in order for reviewers to agree about the risk of bias in studies, particularly when global assessments about the overall risk of bias are performed. However, the reliability of critical appraisals as part of systematic reviews is largely unknown and the inter-rater agreement between individual ratings may be a poor estimate. Typically, in systematic reviews, reconciled ratings are used, where discrepancies between two or more independent reviewer assessments are discussed and reconciled. These reconciled ratings should reduce individual reviewer errors, that is, random errors, and also, to some extent, individual reviewer bias.

Furthermore, whether reported results are prone to bias or whether bias can be shown might be a characteristic of the outcome or the intervention. Wood, Egger, Gluud, et al. (2008) used three datasets of meta-epidemiological studies, that is, studies investigating the associations of quality features and effect sizes (Schulz, Chalmers, 1995, Kjaergard, Villumsen, 2001, Egger, Juni, 2003). The group investigated whether the nature of the intervention and the type of outcome measures influence the effect of allocation concealment and blinding. They found that trials using subjective outcomes showed exaggerated effect sizes when there was inadequate or unclear allocation concealment or lack of blinding. In trials using objective outcomes such as mortality, the association of quality with trial results was negligible. Differentiating drug interventions and non-drug interventions, which was explored in a further analysis, indicated no significant differences on the effect on allocation concealment or blinding.

Other factors that are inherent to datasets may influence our ability to detect effects of trial quality. In a previous AHRQ report on empirical evidence for associations between quality and effect sizes (Hempel et al., 2011) we outlined a number of factors, such as the size of the treatment effect, the condition being treated, the type of outcome measure, and the variation in effect sizes, within the dataset that may potentially influence when quality effects lead to bias and whether the association can be detected in a dataset. The role of some of these factors can be explored in datasets of “known quality”—published datasets where basic characteristics have already been established. Some of the factors and their effects can be tested by using simulations of meta-analyses. Simulations have rarely been applied to meta-analytic questions but can be a powerful tool in systematically assessing the effects of hypothesized factors (e.g., Field, 2001; Field, 2005; Morton, Adams, Suttorp et al., 2004).

To pursue these open questions we combined the use of different meta-epidemiological datasets with “known qualities” and simulation methods for this report.

## Objectives and Key Questions

The objectives of the project were to examine associations between individual and summary indicators of trial quality and effect sizes and to explore factors influencing the detection of associations in meta-epidemiological datasets. The selected quality criteria addressed design and execution factors of the trial as well as the quality of the reporting. For this project we are interested in the association between trial quality criteria and the size of the reported treatment effect. The project aimed to answer the following questions:

- Are the selected quality criteria, individually as well as combined, useful as indicators of bias in diverse clinical contexts? The usefulness was operationalized as predictive validity – whether meeting or not meeting the quality criteria is associated with differential effect sizes in treatment effect trials.
- Which factors influence the presence and the detection of associations between quality and effect sizes? The question was investigated in empirical meta-epidemiological datasets as well as Monte Carlo simulation models.

We expect our results to contribute empirical evidence to the continuing professional debate about the appropriate role of quality criteria in systematic reviews of RCTs.

## Analytic Framework

We tested the hypothesis that the investigated quality criteria show an association with reported effect sizes in different meta-epidemiological datasets and individual clinical areas and meta-analyses. In addition, we investigated moderating factors (such as the effect of heterogeneity and the effect size distribution) that might influence the detection of theses associations.

Figure 1 represents the underlying assumptions.

Figure 1 Analytic framework: presence and detection of associations between trial quality and effect sizes

Figure 1 is a path diagram showing the association between quality and effect sizes. (The association is represented by an arrow pointing from quality to effect sizes). Furthermore, moderators and confounders (represented by additional arrows) are shown to influence the association between quality and effect sizes. Arrows pointing to effect sizes are also shown to represent further influences on effect sizes not related to quality.

The figure shows a simplified diagrammatic representation of the assumption that there is an association between quality features of research studies and the size of the treatment effect reported for the study. This association is represented by the bold arrow. The arrows in the figure indicate the direction of effects, for example quality is assumed to influence the effect sizes (as opposed to an assumption of trial effect sizes influencing the quality of a trial). Each quality criterion is either individually linked to effect sizes or contributes to a quality score that is a composite of individual criteria.

Effect sizes are influenced by many variables in addition to the methodological quality of the research design and the way the study is conducted. The figure depicts the assumption that other variables apart from quality will influence effect sizes; in the regression equation, these are referred to as error. These other variables include the true effect of the intervention, as other potential influences and measurement error; these variables are termed other determinants. Quality variables may explain part of the reported effect sizes but there are other and possibly more important factors that are not quality related (e.g., the efficacy of the treatment).

In addition, we assume that there are factors (moderators) that influence the detection of associations between methodological quality and the reported effect size, represented by the vertical arrows. These factors determine whether an association can be observed in empirical investigations. Potential factors are the size of the treatment effect, issues related to the condition being treated, the type of outcome measure, the variance in effect sizes across included trials (heterogeneity) or distribution characteristics of quality criteria and effect sizes.

The diagram also shows assumptions that need to be made regarding the relationship between these variables, namely that both quality and other factors (such as efficacy) must not be related to the random error that is associated with each study. For example, if there were a factor that predicts both the effect size of a study and the quality of that study there would a relationship between quality and effect size; however, this would be caused by the fact that there was a common cause, and hence the analysis makes the assumption that these variables are unrelated.