# Executive Summary

## Background

Trial design and execution factors are potentially associated with bias in the effect sizes reported for randomized controlled trials. Bias is defined as a systematic deviation of the estimated treatment effect from the true (or population) value. Although a number of factors have been proposed to be associated with bias, an actual association has been empirically confirmed for only a few and the literature shows some conflicting results regarding the association of quality features and effect sizes. Little is known about moderators and confounders that might predict when quality features (or the lack thereof) influence results of research studies and which factors moderate the detection of associations.

In previous research (Hempel et al., 2011), we investigated the effect of the individual criteria used by the Cochrane Back Review Group (CBRG) and a quantitative summary score derived from the criteria. The set covers established criteria internal validity and quality of the reporting criteria as well as quality indicators that have rarely been assessed or shown to be indicators of bias. Previous results showed that the criteria, in particular when combined as a quantitative summary score, differentiated high and low quality trials in two out of three meta-epidemiological datasets which comprised a number of individual meta-analyses and included trials. High- and low-quality trials, as measured by the selected criteria, showed a trend for differences in reported effect sizes, with low quality trials exaggerating treatment effects. In order to continue to test the generalizability of quality criteria and the situations where they may be most useful, we expanded our analytic capability by including a new meta-epidemiological dataset in our analyses and investigated factors that may explain when quality is associated with effect size and when these associations can be detected in datasets.

The association between quality features and effect sizes is complex, and the conditions in which quality is most likely to be associated with bias warrant further exploration. We expect our results to contribute empirical evidence to the continuing professional debate about the appropriate role of quality criteria in systematic reviews of randomized controlled trials.

## Objectives and Key Questions

The objectives of the project were to examine associations between individual and summary indicators of trial quality and effect sizes and to explore factors influencing the detection of associations in meta-epidemiological datasets. The selected quality criteria address design and execution factors of the trial as well as the quality of the reporting. We are interested in the association between trial quality criteria and the size of the reported treatment effect; that is, whether trials meeting the quality criteria reported different treatment effects than trials not meeting quality criteria. The project aimed to answer the following questions:

- Are the selected quality criteria, individually as well as combined, useful as indicators of bias in diverse clinical contexts? The usefulness was operationalized as predictive validity – whether meeting or not meeting the quality criteria is associated with differential effect sizes in treatment effect trials.
- Which factors influence the presence and the detection of associations between quality and effect sizes? The question was investigated in empirical meta-epidemiological datasets as well as Monte Carlo simulation models.

## Methods

### Association Between Quality and Effect Sizes in Empirical Datasets

We applied 11 quality criteria to 4 large meta-epidemiological datasets. These datasets included a variety of meta-analyses covering a wide range of clinical fields. Each meta-analysis contributed between 3 and 45 individual trials. The first dataset was derived from all CBRG reviews of non-surgical treatment for non-specific low back pain in the Cochrane Library 2005, issue 3; the dataset included 216 individual trials. For the second dataset we searched prior systematic reviews and meta-analyses conducted by Agency for Healthcare Research and Quality (AHRQ)-funded Evidence-based Practice Centers (EPCs) with the goal of assembling a dataset with a wide range of clinical topics and interventions; this dataset included 165 trials. The third dataset was obtained by replicating a selection of trials used in a published meta-epidemiological study that demonstrated associations between quality and the size of treatment effects; this dataset included 100 trials. For the purpose of this report we assembled an additional dataset with ‘known qualities’. This fourth dataset was based on another published meta-epidemiological dataset. One of the selection criteria for the trials that were included in this dataset was that meta-analyses used to establish the dataset had to report evidence of heterogeneity across trials.

We assessed quality criteria and risk of bias indicators for all included trials. We used the CBRG quality criteria, which cover 11 quality features (generation of the randomization sequence, concealment of treatment allocation, similarity of baseline values, blinding of outcome assessors, blinding of care providers, blinding of patients, acceptable dropout rate and stated reasons for withdrawals, intention-to-treat analysis, similarity of co-interventions, acceptable compliance, and similar timing of outcome assessment. In addition, we applied the Jadad criteria (randomization, blinding, withdrawals and dropouts, total score), criteria proposed by Schulz (concealment of treatment allocation, sequence generation, inclusion in the analysis of all randomized participants, double blinding), and the Cochrane Risk of Bias tool (sequence generation; allocation concealment; blinding of participants, personnel and outcome assessors; incomplete outcome data; selective outcome reporting; other sources of bias; overall risk of bias).

For all datasets we calculated odds ratios for datasets with dichotomous outcomes and effect sizes for datasets with continuous outcomes. We investigated associations between quality and reported treatment effects in meta-regression by calculating the differences in effect sizes or ratios of odds ratios (ROR) of trials meeting quality criteria compared to those that did not. A negative effect size difference indicated that trials meeting quality criteria (high-quality trials) reported smaller effect sizes and a ROR less than 1 indicates that high-quality trials reported a smaller treatment effect compared to those trials that did not meet the quality criteria.

### Heterogeneity and Effect Size Distributions

In a further analysis we explored the heterogeneity and effect size distribution shown in the different datasets. The meta-epidemiological datasets comprise different meta-analyses that each contain individual trials. We used I^2^ to measure the percent of variation across trials in each meta-analysis datasets that is due to heterogeneity. In addition, we computed I^2^ estimates across all trials at the meta-epidemiological dataset level as an indicator of the variation represented by the datasets. In order to address the variation in distributions found across datasets, we aimed to sample individual datasets to mirror plotted distributions found in the various analyzed datasets. We used a non-parametric approach and ranked the studies included in dataset 1 and dataset 2 from the smallest to the largest effect size. We then matched them and assigned dataset 2 effect sizes to the dataset 1 quality criteria based on the rankings of the effect sizes within the datasets.

### Monte Carlo Simulations

Finally, we created datasets by Monte Carlo simulation methods to systematically explore factors that influence the power to detect an association between quality and effect sizes in meta-epidemiological datasets. We determined the properties of the sampling distribution of the meta-regression estimates under different conditions to determine the factors that influence the likelihood of detecting associations between quality and effect sizes. We generated data sampled from populations that matched three meta-epidemiological datasets in terms of number of trials, sample size per trial and level of heterogeneity in the overall dataset. For each of the datasets we systematically altered two parameters: First, we randomly generated populations with quality effects of 0.1 and 0.2 (effect size differences between high and low quality trials). We modeled heterogeneity by adding a variance parameter to the simulations – each meta-analysis was comprised of studies sampled from a population with a specified effect size. Effect sizes were generated at the study level, and then (for heterogeneity) a random parameter was added to the effect size, to introduce population level heterogeneity. We used a heterogeneity value that matched observed results in the empirical datasets. To model reduced heterogeneity we halved the value of the parameter that was added and in addition used a heterogeneity parameter of zero. Outcome data were then generated for individual trial participants in for intervention and control groups for each trial, with 50 percent of individuals assigned to each group.

This gave 3 (levels of heterogeneity) × 2 (quality effects) = 6 cells in the simulation for each dataset. For each of these cells in the simulation we generated and analyzed 1000 datasets. A function was written in R version 2.12 to generate data, analyze simulations, and aggregate results.

## Results

### Association Between Quality and Effect Sizes in Empirical Datasets

Results for evidence of bias varied between meta-epidemiological datasets, clinical fields, and individual meta-analyses. In the new empirical dataset (‘Heterogeneity set’) compiled specifically for this report, associations between CBRG criteria and effect sizes were small, for example the ROR between unconcealed and concealed trials was 0.89 (95% CI: 0.73, 1.09). None of the associations was statistically significant but the large majority of RORs indicated that trials that did not meet investigated quality criteria such as concealment of treatment allocation, similarity of baseline values, blinding of outcome assessors, blinding of care providers, blinding of patients, use of intention-to-treat analysis, similarity of co-interventions, and similar timing of outcome assessment reported slightly larger treatment effects. Results for other published quality criteria and risk of bias indicators applied in parallel showed similar results.

Based on a quantitative summary score for the CBRG criteria, the data for the new meta-epidemiological dataset showed that a cut-off of six or more criteria met (out of 11) differentiated high- and low-quality trials best (ROR 0.86; 95% CI: 0.70, 1.06). Similarly, in two of the other meta-epidemiological datasets a cut-off of five or six criteria showed the largest differences in effect sizes (e.g., cut-off 5 criteria met, effect size difference -20, 95% CI: -0.34, -0.06 and ROR 0.79, 95% CI: 0.63, 0.95) while one dataset showed no effect of quality (effect size difference 0.02, 95% CI: -0.015, 0.062). The difference in reported treatment effects based on the quantitative summary score only marginally exceeded those of individually criteria and the difference was not statistically significant in this new dataset. Across datasets, most consistent associations between quality and effect sizes were found for allocation concealment with concealed trials showing smaller treatment effects.

In individual meta-analyses that constituted each meta-epidemiological datasets, high-quality trials were sometimes associated with smaller reported effect sizes and sometimes with the opposite effect (associated with larger effect sizes). A correction for clustering by meta-analysis had no noticeable effect on estimates of the associations between quality and effect sizes.

Based on these results, it cannot be determined whether the proposed extended list of quality criteria should be applied regularly when judging the quality of studies (key question 1). However, in order to evaluate this finding, it is important to know the quality of the applied test and whether the lack of observed effect indicates conclusively that trial quality is not associated with reported effect sizes.

### Heterogeneity and Effect Size Distributions

The amount of heterogeneity in dataset 1 estimated by I^2^ ranged from 8.9 to 85.3 percent in individual trials and the overall estimated heterogeneity for the entire dataset was 72.4 percent. In dataset 2 (EPC reports), individual I^2^ estimates were generally higher and ranged from 26.2 to 99.4 percent and the overall dataset estimate was 97.5 percent. Several meta-analyses in dataset 3 ‘Pro-bias’ showed no evidence of heterogeneity; the overall dataset heterogeneity estimate was 59.6 percent. Some individual estimates were not statistically significant in dataset 4 (‘Heterogeneity set’) and the overall database estimate was 60 percent, which was comparable to dataset 1 and 3, although heterogeneity across studies was one of the explicit inclusion criteria for the selection of meta-analyses that were compiled for this dataset.

The effect size distributions varied across meta-epidemiological datasets; in particular the dataset 2 (EPC reports) distribution was less symmetric and bell-shaped than those of the other datasets. To investigate whether the distribution characteristics are correlated with the difference in associations between quality and effect sizes between datasets, we used a non-parametric sampling approach to mirror the distribution of dataset 2 in other datasets. The effect size histograms showed that the sampling method was successful in creating a similar distribution shape. With regard to associations between quality and effect sizes, dataset 1 (Back pain) which had originally shown consistent effects of quality now showed conflicting results—some criteria were associated with effect sizes, some were not, and the direction of effects varied across quality criteria. To investigate whether this observation could be replicated in another dataset, we applied the process to dataset 3 (‘Pro-bias’). The difference between the original data and the new data was less clear in this dataset. This finding may in part be due to inconsistencies across quality criteria that had appeared in the original data and in part to the fact that it is difficult to compare ratios of odds ratios and effect sizes.

### Monte Carlo Simulations

Trial quality is typically explored as a potential source of heterogeneity across trials; however, the simulation analyses show that additional heterogeneity can reduce the power to detect statistically significant trial quality effects (key question 2).

In Monte Carlo simulations designed to reflect the characteristics of the empirical datasets, power to detect quality moderator effects in three sets of data was variable, and for many datasets of study parameters power was low. Even large quality effects mirroring substantial differences in reported treatment effects between high- and low-quality trials, in simulations set up to maximize statistical power (by assigning 50 percent of trials to high quality and 50 percent to low quality) could not be detected in the presence of a large amount of additional heterogeneity across trials, that is heterogeneity not due to quality.

These results indicate that failure to detect quality effects should not be taken as evidence that there are no quality effects. Furthermore, based on our analyses, individual meta-analyses should include steps to minimize heterogeneity through the inclusion of additional study level covariates. These refinements can reduce unexplained heterogeneity and thereby aid the investigation of quality effects and the potential for bias.

## Future Research

Our analyses have shown that it is challenging to detect effects of study quality on reported treatment effects. This is the case for individual meta-analyses as well as meta-epidemiological datasets. From this it follows that the failure to detect a statistically significant quality effect should not be interpreted as meaning that a quality effect is not present.

Future studies that investigate the effects of quality as a moderator of outcomes in randomized trials should take steps to ensure that unexplained heterogeneity is minimized. In meta-epidemiological datasets, minimizing heterogeneity can be achieved though many means (e.g., utilizing a larger number of trials). Following our analyses, individual meta-analyses might achieve an adequate level of heterogeneity through the inclusion of additional study-level covariates when investigating the association between trial quality and effect sizes.

More empirical evidence is needed to determine which quality features are likely to influence reported effect sizes, and under which conditions. This question is of particular importance for the critical appraisal of systematic reviews when aiming to summarize the existing evidence appropriately.

## Conclusion

Although trial quality may explain some amount of heterogeneity across trial results in meta-analyses, the amount of additional heterogeneity in effect sizes is a crucial factor determining when associations between quality and effect sizes can be detected. Detecting quality moderator effects requires more statistically powerful analyses than are employed in many investigations.