# Quality Rating Form and References of Included Trials

## Quality Rating Forms

Original Quality Items

Scoring Guidelines Cochrane Back Pain Group

Jadad Scale

Schulz (1995) Scoring

Cochrane Risk of Bias Tool

## Description of Monte Carlo Simulation

The Monte Carlo simulation was carried out by generating individual patient data for each study (trial). Individual patient data was then used to calculate summary statistics for each study, and these are then subjected to meta-analysis. The results of the meta-analyses are then summarized and returned.

An R function, presented below, runs the simulations.

Example: To run a simulation of a meta-analysis with an additive treatment effect variance of 0.28 (population variance) of 0.28, a low quality effect of zero, 216 studies per meta-analysis, an average additive treatment effect for each study of 0.1, 38 patients per arm:

atev0.28_lqe0.1 <- runMetaSim(ATEVariance=0.28,
lowQualityEffect=.1, nStudies=20, additiveTreatmentEffect=0.1,
nPatients = 100, nMetas = 1000)

This produces the following output:

  c(1:nMetas)     noModeratorEst     noModeratorSig
noModeratorI2
 Min.   :   1.0   Min.   :-0.52504   Min.   :0.000   Min.
:78.96
 1st Qu.: 250.8   1st Qu.:-0.22592   1st Qu.:0.000   1st
Qu.:90.72
 Median : 500.5   Median :-0.15397   Median :0.000   Median
:92.50
 Mean   : 500.5   Mean   :-0.14912   Mean   :0.247   Mean
:92.04
 3rd Qu.: 750.2   3rd Qu.:-0.06858   3rd Qu.:0.000   3rd
Qu.:93.90
 Max.   :1000.0   Max.   : 0.22088   Max.   :1.000   Max.
:96.52
 noModeratorTau2   lowQualityModEst   lowQualityModSig
 Min.   :0.07644   Min.   :-0.84262   Min.   :0.000
 1st Qu.:0.20129   1st Qu.:-0.25805   1st Qu.:0.000
 Median :0.25594   Median :-0.10680   Median :0.000
 Mean   :0.26746   Mean   :-0.10629   Mean   :0.094
 3rd Qu.:0.32325   3rd Qu.: 0.04945   3rd Qu.:0.000
 Max.   :0.59768   Max.   : 0.69177   Max.   :1.000

noModeratorEst is the treatment effect, the mean treatment effect is -0.099, when the population treatment effect was -0.149. The population ATE for high quality studies was 0.1, however, the effect of low quality studies was also 0.1, and half of the studies were low quality, giving a population mean of 0.15.

noModeratorSig is whether or not the treatment effect was found to be significant in the meta-analysis, the mean of this variable gives the power to detect the effect, hence the power to detect an effect when quality was not taken into account was 0.247.

noModeratorI2 is the I-squared for the analysis with no moderator. The median is 92.5.

noModeratorTau2 is the value for Tau-squared when a moderator is not included. The value here is 0.27.

lowQualityModEst is the estimate of the effect of a low quality study. The mean is -0.107, when the population mean entered into the simulation is 0.10.

lowQualityModEst is the effect of the moderator. The mean here is 0.106, compared with a population value of 0.10.

lowQualityModSig is the significance of the low quality moderator. The power of the study to detect a low quality effect is given by the mean of this variable – in this case, the power to detect an effect of quality is 0.094 (9.4%).

Steps in the analysis

1. For each study, in each meta-analysis, an effect size is generated. In the case of zero treatment effect variance, this effect is equal for all studies. In the case of a simulation with additional heterogeneity, a random normal variable with mean 0 and variance equal to the treatment effect variance is calculated, and this is added to the treatment effect of each study. In this way, the mean treatment effect is unchanged, but the variance of the treatment effect is increased.
2. For each study, in each meta-analysis, control and intervention samples are generated. For each study a normally distributed random variable is created, with mean=0 and sd=1 for the control group. For the intervention group, a normally distributed random variable with mean = treatment effect for that study and sd = 1. These data generated using the rnorm() function, in R BASE.
3. The effect size for each study is generated using escalc(), in the the R metafor package.
4. Studies are grouped into meta-analyses. Each meta-analysis is analyzed twice using rma(), once with low quality as a moderator, and once without. The parameter estimates are stored for both analyses, as is whether or not the result was statistically significant. The I-squared and tau-squared for the analysis with no moderator are stored.
5. The function returns a summary of these stored data.

rm(list=ls())
library(metafor)
library(compiler)
	#Define a function to return mean and SD from the same vector.
	meanSD <- function(x) {
		   sampleMean <- mean(x)
		   sampleSD <- sd(x)
		   x <- c(sampleMean, sampleSD)
		   return(x)
		   }

#First define function and set defaults - defaults are overridden by arguments passed
by function call.

runMetaSim <- function( nMetas = 1000,
	   #Number of meta-analyses to be simulated
					  nStudies = 100,
	   #Number of studies per meta-analysis
					  nPatients = 100,
	   #Number of patients per study
					  additiveTreatmentEffect = 0.1,  #This
is the additive effect, so it's in log odds, gamma_0
					  ATEVariance = 1,
		#A random variable to introduce study level heterogeneity - nu_1,
					  method = "DL" ,
			#Method to combine data, FE for fixed, DL, etc for DerSimonian-Laird, etc
					  lowQualityEffect= 0.1  ,
		#increase in effect size associated with low
					  lowQualityRatio = 0.5	)
		#Set proportion of studies that have low quality

	{
	
		metaChars <- data.frame(c(1:nMetas))  #Create data frame with number of
rows equal to number of simulations

		#Now generate study parameters

		metaStudies <- data.frame(c(1:(nMetas*nStudies))) #Generate data
frame containing one row for each study in meta-analysis

		metaStudies$metaAnalysisRepetitionNumber <- rep((c(1:nMetas)), nStudies)

		names(metaChars)[1] <- "metaAnalysisRepetitionNumber"
	
		metaStudies <- metaStudies[ order(metaStudies$metaAnalysisRepetitionNumber) ,]

		metaStudies  <- merge(metaStudies, metaChars, sort=TRUE,
by="metaAnalysisRepetitionNumber")
		metaStudies$rowNumber <- c(0:(nStudies*nMetas-1))
		metaStudies$lowQualityEffect<- lowQualityEffect

		metaStudies$studyNumberWithinMeta <- (metaStudies$rowNumber %% nStudies )  + 1
		metaStudies$lowQuality <- ifelse((metaStudies$studyNumberWithinMeta / nStudies
) > lowQualityRatio, 1, 0)

		#Generate additive treatment effect for each study.
		##############################

		metaStudies$additiveTreatmentEffect <- additiveTreatmentEffect
#That's the additive treatment effect
		metaStudies$studyATE <- rnorm((nMetas*nStudies), mean=0, sd=ATEVariance**0.5
)		  #That's where the random effect gets added.  The size of the randome effect

									#depends on ATE
variance
	metaStudies$additiveTreatmentEffect <- metaStudies$additiveTreatmentEffect +
metaStudies$studyATE
	metaStudies$additiveTreatmentEffect <- metaStudies$additiveTreatmentEffect +
	metaStudies$lowQuality * lowQualityEffect    #Low quality
studies have larger effect sizes.

	metaStudies$n <- metaStudies$n <-  nPatients

	meanNs <- aggregate(metaStudies$n,
by=list(metaStudies$metaAnalysisRepetitionNumber), mean)

	names(meanNs)[1] <- "metaAnalysisRepetitionNumber"
	names(meanNs)[2] <- "studyMeanNs"

	metaStudies <- merge(metaStudies, meanNs, by="metaAnalysisRepetitionNumber")

	metaStudies$n <- round(( nPatients / metaStudies$studyMeanNs * metaStudies$n) ,
digits=0)

	###################################


	metaStudies$controlMean <- apply(metaStudies, 1, function(x) mean(rnorm(mean=0,
sd=1, n=nPatients)))   #Generate raw data form control group for each study, and find
mean and SD
	metaStudies$controlSD <- apply(metaStudies, 1, function(x) sd(rnorm(mean=0,
sd=1, n=nPatients)))


	metaStudies$interMean <- apply(metaStudies, 1, function(x) mean(rnorm(mean=0,
sd=1, n=nPatients)))  + metaStudies$additiveTreatmentEffect
			
		   #Generate raw data from treatment group for each study, and find
mean and SD

	metaStudies$interSD <- apply(metaStudies, 1, function(x) sd(rnorm(mean=0, sd=1,
n=nPatients)))

	es <- escalc( m1i =  controlMean,    #Use escalc()
function, in metafor library, to generate effect size for each study
		m2i =  interMean,
		sd1i = controlSD,
		sd2i = interSD,
		n1i = n,
		n2i = n,
		measure = "SMD",
		data=metaStudies)

	metaStudies <- cbind(metaStudies, es)
	resultsNoModerator <- as.list(c(1:nMetas))
	resultsWithModerator <- as.list(c(1:nMetas))
	pValuesAndEsts <- WithModerator <- as.data.frame(c(1:nMetas))

	for(loop in c(1:nMetas)) {
	
		noMods <- with( subset(metaStudies,
metaStudies$metaAnalysisRepetitionNumber==loop),	{ #Run meta-analyses with no
moderator
			rma(yi, vi, method=method ) }
		 )

		lowQualityMod <- with( subset(metaStudies,
metaStudies$metaAnalysisRepetitionNumber==loop),  { #Run meta-analyses with moderator
		  rma(yi, vi, mods=~lowQuality, method=method ) }
		 )

		#Extract estimates, and significance of estimates, from data.
		pValuesAndEsts$noModeratorEst[loop] <- noMods[[1]]
		pValuesAndEsts$noModeratorSig[loop] <- ifelse( noMods[[4]] < 0.05, 1, 0)
		pValuesAndEsts$noModeratorI2[loop] <- noMods$I2
		pValuesAndEsts$noModeratorTau2[loop] <- noMods$tau2

		pValuesAndEsts$lowQualityModEst[loop] <-  lowQualityMod[[1]][[2]]
		pValuesAndEsts$lowQualityModSig[loop] <- ifelse( lowQualityMod[[4]][[2]]
< 0.05, 1, 0)


	}

	return( summary(pValuesAndEsts ))

}

#########################End of runMetaSim function.



start.t <- proc.time()		#Use proc.time functions to record time taken by
simulation

atev0.28_lqe0.1 <- runMetaSim(ATEVariance=0.28, lowQualityEffect=.1, nStudies=20,
     additiveTreatmentEffect=0.1, nPatients = 100, nMetas = 100)

end.t <- proc.time()
end.t[3] - start.t[3]
start.t <- proc.time()
atev0.28_lqe0.1

## References of Trials Included in the “Heterogeneity”- Set

[no author]. A prospective trial of intravenous streptokinase in acute myocardial infarction (I.S.A.M.). Mortality, morbidity, and infarct size at 21 days. The I.S.A.M. Study Group. N Engl J Med. Jun. 5. 1986;314(23):1465-71. [pmid: 2871492].
[no author]. A randomized trial of aspirin and sulfinpyrazone in threatened stroke. The Canadian Cooperative Study Group. N Engl J Med. Jul. 13. 1978;299(2):53-9. [pmid: 351394].
[no author]. A randomized trial of propranolol in patients with acute myocardial infarction. I. Mortality results. JAMA. Mar. 26. 1982;247(12):1707-14. [pmid: 7038157].
[no author]. A randomized, controlled trial of aspirin in persons recovered from myocardial infarction. JAMA. Feb. 15. 1980;243(7):661-9. [pmid: 6985998].
[no author]. Aspirin in coronary heart disease. The Coronary Drug Project Research Group. J Chronic Dis. Oct. 1976;29(10):625-42. [pmid: 789390].
[no author]. Clofibrate and niacin in coronary heart disease. JAMA. Jan. 27. 1975;231(4):360-81. [pmid: 1088963]. Controlled trial of soya-bean oil in myocardial infarction. Lancet. Sep. 28. 1968;2(7570):693-9. [pmid: 4175085].
[no author]. Effectiveness of intravenous thrombolytic treatment in acute myocardial infarction. Gruppo Italiano per lo Studio della Streptochinasi nell'Infarto Miocardico (GISSI). Lancet. Feb. 22. 1986;1(8478):397-402. [pmid: 2868337].
[no author]. Effects of encainide, flecainide, imipramine and moricizine on ventricular arrhythmias during the year after acute myocardial infarction: the CAPS. The Cardiac Arrhythmia Pilot Study (CAPS) Investigators. Am J Cardiol. Mar. 1. 1988;61(8):501-9. [pmid: 2894169].
[no author]. European Infarction Study (E.I.S.). A secondary prevention study with slow release oxprenolol after myocardial infarction: morbidity and mortality. Eur Heart J. Mar. 1984;5(3):189-202. [pmid: 6373264].
[no author]. International mexiletine and placebo antiarrhythmic coronary trial: I. Report on arrhythmia and other findings. Impact Research Group. J Am Coll Cardiol. Dec. 1984;4(6):1148-63. [pmid: 6209318].
[no author]. Ischaemic heart disease: a secondary prevention trial using clofibrate. Report by a research committee of the Scottish Society of Physicians. Br Med J. Dec. 25. 1971;4(5790):775-84. [pmid: 4943606]. Low-fat diet in myocardial infarction: A controlled trial. Lancet. Sep. 11. 1965;2(7411):501-4. [pmid: 4158171].
[no author]. Persantine and aspirin in coronary heart disease. The Persantine-Aspirin Reinfarction Study Research Group. Circulation. Sep. 1980;62(3):449-61.
[no author]. Phenytoin after recovery from myocardial infarction. Controlled trial in 568 patients. Lancet. Nov. 13. 1971;2(7733):1055-7. [pmid: 4106911].
[no author]. Preliminary report: effect of encainide and flecainide on mortality in a randomized trial of arrhythmia suppression after myocardial infarction. The Cardiac Arrhythmia Suppression Trial (CAST) Investigators. N Engl J Med. Aug. 10. 1989;321(6):406-12. [pmid: 2473403].
[no author]. Randomised trial of intravenous streptokinase, oral aspirin, both, or neither among 17,187 cases of suspected acute myocardial infarction: ISIS-2. ISIS-2 (Second International Study of Infarct Survival) Collaborative Group. Lancet. Aug. 13. 1988;2(8607):349-60. [pmid: 2899772].
[no author]. Reduction in mortality after myocardial infarction with long-term beta-adrenoceptor blockade. Multicentre international study: supplementary report. Br Med J. Aug. 13. 1977;2(6084):419-21. [pmid: 329943].
[no author]. Streptokinase in acute myocardial infarction. European Cooperative Study Group for Streptokinase Treatment in Acute Myocardial Infarction. N Engl J Med. Oct. 11. 1979;301(15):797-802. [pmid: 481511].
[no author]. Streptokinase in recent myocardial infarction: a controlled multicentre trial. European working party. Br Med J. Aug. 7. 1971;3(5770):325-31. [pmid: 4934187].
[no author]. The effect of pindolol on the two years mortality after complicated myocardial infarction. Eur Heart J. Jun. 1983;4(6):367-75. [pmid: 6617682].
[no author]. Timolol-induced reduction in mortality and reinfarction in patients surviving acute myocardial infarction. N Engl J Med. Apr. 2. 1981;304(14):801-7. [pmid: 7010157].
[no author]. Trial of clofibrate in the treatment of ischaemic heart disease. Five-year study by a group of physicians of the Newcastle upon Tyne region. Br Med J. Dec. 25. 1971;4(5790):767-75. [pmid: 4943605].
[no author]. United Kingdom transient ischaemic attack (UK-TIA) aspirin trial: interim results. UK-TIA Study Group. Br Med J (Clin Res Ed). Jan. 30. 1988;296(6618):316-20.
Aber CP, Bass NM, Berry CL, Carson PH, Dobbs RJ, Fox KM, et al. Streptokinase in acute myocardial infarction: a controlled multicentre study in the United Kingdom. Br Med J. Nov. 6. 1976;2(6044):1100-4. [pmid: 791442].
Abraham AS, Rosenmann D, Kramer M, Balkin J, Zion MM, Farbstien H, et al. Magnesium in the prevention of lethal arrhythmias in acute myocardial infarction. Arch Intern Med. Apr. 1987;147(4):753-5. [pmid: 3548627].
Adam D. Five-Day therapy with cefpodoxime versus ten-day treatment with cefaclor in infants with acute otitis media. Infection. 1995;23:398-9.
Alario AJ, Lewander WJ, Dennehy P, Seifer R, Mansell AL. The efficacy of nebulized metaproterenol in wheezing infants and young children. Am J Dis Child. Apr. 1992;146(4):412-8. [pmid: 1558072].
Amery A, Roeber G, Vermeulen HJ, Verstraete M. Single-blind randomised multicentre trial comparing heparin and streptokinase treatment in recent myocardial infarction. Acta Med Scand Suppl. 1969;505:1-35. [pmid: 4911123].
Andersen MP, Bechsgaard P, Frederiksen J, Hansen DA, Jurgensen HJ, Nielsen B, et al. Effect of alprenolol on mortality among patients with definite or suspected acute myocardial infarction. Preliminary results. Lancet. Oct. 27. 1979;2(8148):865-8. [pmid: 90964].
Arguedas A, Loaiza C, Herrera M, Mohs E. Comparative trial of 3-day azithromycin versus 10-day amoxycillin/clavulanate potassium in the treatment of children with acute otitis media with effusion. Int J Antimicrob Agents. Apr. 1996;6(4):233-8. [pmid: 18611713].
Arguedas A, Loaiza C, Rodriguez F, Herrera ML, Mohs E. Comparative trial of 3 days of azithromycin versus 10 days of clarithromycin in the treatment of children with acute otitis media with effusion. J Chemother. Feb. 1997;9(1):44-50. [pmid: 9106017]. Aronovitz G. A multicenter, open label trial of azithromycin vs. amoxicillin/ clavulanate for the management of acute otitis media in children. Pediatr Infect Dis J. Sep. 1996;15(9 Suppl):S15-9. [pmid: 8878241].
Aspenstroem G, Korsan-Bengtsen K. A Double Blind Study of Dicumarol Prophylaxis in Coronary Heart Disease. Acta Med Scand. Nov. 1964;176:563-75. [pmid: 14223532].
Baber NS, Evans DW, Howitt G, Thomas M, Wilson T, Lewis JA, et al. Multicentre post-infarction trial of propranolol in 49 hospitals in the United Kingdom, Italy, and Yugoslavia. Br Heart J. Jul. 1980;44(1):96-100. [pmid: 7000100].
Barber JM, Boyle DM, Chaturvedi NC, Singh N, Walsh MJ. Practolol in acute myocardial infarction. Acta Med Scand Suppl. 1976;587:213-9. [pmid: 130058].
Barnett ED, Teele DW, Klein JO, Cabral HJ, Kharasch SJ. Comparison of ceftriaxone and trimethoprim-sulfamethoxazole for acute otitis media. Greater Boston Otitis Media Study Group. Pediatrics. Jan. 1997;99(1):23-8. [pmid: 8989332].
Baroffio R. [Efficacy of a randomized treatment with intravenous streptokinase in evolving myocardial infarction. In-hospital clinical and radionuclide evaluation and a follow-up]. Minerva Cardioangiol. Oct. 1986;34(10):607-14. [pmid: 3543729].
Bassand JP, Faivre R, Becque O, Habert C, Schuffenecker M, Petiteau PY, et al. Effects of early high-dose streptokinase intravenously on left ventricular function in acute myocardial infarction. Am J Cardiol. Sep. 1. 1987;60(7):435-9. [pmid: 3307367].
Bastian BC, Macfarlane PW, McLauchlan JH, Ballantyne D, Clark P, Hillis WS, et al. A prospective randomized trial of tocainide in patients following myocardial infarction. Am Heart J. Dec. 1980;100(6 Pt 2):1017-22. [pmid: 6778189].
Benda L, Haider M, Ambrosch F. [Results of the Austrian myocardial infarction study on the effects of streptokinase (author's transl)]. Wien Klin Wochenschr. Dec. 9. 1977;89(23):779-83. [pmid: 339553].
Bett JH, Castaldi PA, Hale GS, Isbister JP, McLean KH, O'Sullivan EF, et al. Australian multicentre trial of streptokinase in acute myocardial infarction. Lancet. Jan. 13. 1973;1(7794):57-60. [pmid: 4118646].
Boulesteix J, Dubreuil C, Moutot M, Rezvani Y. Rosembaum. Cefpodoxime proxteil 5 jours versus cefixime 8 jours, dans le traitment des otites moyennes aigues de l'enfant. Med Mal Infect. 1995;25:534-9.
Breddin K, Ehrly AM, Fechler L, Frick D, Konig H, Kraft H, et al. [Short-term fibrinolytic treatment in acute myocardial infarction]. Dtsch Med Wochenschr. Apr. 27. 1973;98(17):861-73. [pmid: 4571884]. Breddin K, Loew D, Lechner K, Uberla K, Walter E. Secondary prevention of myocardial infarction. Comparison of acetylsalicylic acid, phenprocoumon and placebo. A multicenter two-year prospective study. Thromb Haemost. Feb. 28. 1979;41(1):225-36. [pmid: 483232].
Britton M, Helmers C, Samuelsson K. High dose acetylsalicylic acid after cerebral infarction: a Swedish co-operative study. Stroke. 1987;18:325-34. [pmid: 2882626].
Brozanski BS, Jones JG, Gilmour CH, Balsan MJ, Vazquez RL, Israel BA, et al. Effect of pulse dexamethasone therapy on the incidence and severity of chronic lung disease in the very low birth weight infant. J Pediatr. May. 1995;126(5 Pt 1):769-76. [pmid: 7752005].
Bussmann WD, Passek D, Seidel W, Kaltenbach M. Reduction of CK and CK-MB indexes of infarct size by intravenous nitroglycerin. Circulation. Mar. 1981;63(3):615-22. [pmid: 6780232].
Cairns JA, Gent M, Singer J, Finnie KJ, Froggatt GM, Holder DA, et al. Aspirin, sulfinpyrazone, or both in unstable angina. Results of a Canadian multicenter trial. N Engl J Med. Nov. 28. 1985;313(22):1369-75. [pmid: 3903504].
Carlson LA, Rosenhamer G. Reduction of mortality in the Stockholm Ischaemic Heart Disease Secondary Prevention Study by combined treatment with clofibrate and nicotinic acid. Acta Med Scand. 1988;223(5):405-18. [pmid: 3287837].
Ceremuzynski L, Jurgiel R, Kulakowski P, Gebalska J. Threatening arrhythmias in acute myocardial infarction are prevented by intravenous magnesium sulfate. Am Heart J. Dec. 1989;118(6):1333-4. [pmid: 2589170].
Chamberlain DA, Jewitt DE, Julian DG, Campbell RW, Boyle DM, Shanks RG. Oral mexiletine in high-risk patients after myocardial infarction. Lancet. Dec. 20-27. 1980;2(8208-8209):1324-7. [pmid: 6109149].
Chamberlain JM, Boenning DA, Waisman Y, Ochsenschlager DW, Klein BL. Single-dose ceftriaxone versus 10 days of cefaclor for otitis media. Clin Pediatr (Phila). Nov. 1994;33(11):642-6. [pmid: 7859421].
Chaput de Saintonge DM, Levine DF, Savage IT, Burgess GW, Sharp J, Mayhew SR, et al. Trial of three-day and ten-day courses of amoxycillin in otitis media. Br Med J (Clin Res Ed). Apr. 10. 1982;284(6322):1078-81.
Cohen R, de La Rocque F, Boucherat M. al E. Etude randomisee cefpodoxime proxetil 5 jours versus amoxilline-acide calvulanique 8 jours dans le traitment de l'otite moyenne aigue de l'enfant. Med Mal Infect. 1997;27:596-602.
Cohn JN, Franciosa JA, Francis GS, Archibald D, Tristani F, Fletcher R, et al. Effect of short-term infusion of sodium nitroprusside on mortality rate in acute myocardial infarction complicated by left ventricular failure: results of a Veterans Administration cooperative study. N Engl J Med. May. 13. 1982;306(19):1129-35. [pmid: 7040956].
Conrad LL, Kyriacopoulos JD, Wiggins CW, Honick GL. Prevention of Recurrences of Myocardial Infarction; a Double-Blind Study of the Effectiveness of Long-Term Oral Anticoagulant Therapy. Arch Intern Med. Sep. 1964;114:348-58. [pmid: 14171625].
Corwin MJ, Weiner LB, Daniels D. Efficacy of oral antibiotics for the treatment of persistent otitis media with effusion. Int J Pediatr Otorhinolaryngol. Apr. 1986;11(2):109-12. [pmid: 3488978].
Cribier A, Berland J, Saoudi N, Redonnet M, Moore N, Letac B. Intracoronary streptokinase, OK! ... Intravenous streptokinase, first? Heparin or intravenous streptokinase in acute infarction: preliminary results of a prospective randomized trial with angiographic evaluation in 44 patients. Haemostasis. 1986;16(Suppl 3):122-9. [pmid: 3770538].
Daly K, Giebink G, Lindgren B, Anderson R. Controlled clinical trial for prevention of chronic otitis media with effusion. Lim DJ, editor. Recent advances in otitis media. Toronto. BC Decker. 1988:247-50.
Daniel RR. Comparison of azithromycin and co-amoxiclav in the treatment of otitis media in children. J Antimicrob Chemother. Jun. 1993;31(Suppl E):65-71. [pmid: 8396099].
Dewar HA, Stephenson P, Horler AR, Cassells-Smith AJ, Ellis PA. Fibrinolytic therapy of coronary thrombosis. Controlled trial of 75 cases. Br Med J. Apr. 6. 1963;1(5335):915-20. [pmid: 14027424].
Dioguardi N, Lotto A, Levi GF, Rota M, Proto C, Mannucci PM, et al. Controlled trial of streptokinase and heparin in acute myocardial infarction. Lancet. Oct. 23. 1971;2(7730):891-5. [pmid: 4106657].
Durand M, Sardesai S, McEvoy C. Effects of early dexamethasone therapy on pulmonary mechanics and chronic lung disease in very low birth weight infants: a randomized, controlled trial. Pediatrics. Apr. 1995;95(4):584-90. [pmid: 7700763].
Durand P, Asseman P, Pruvost P, Bertrand ME, LaBlanche JM, Thery C. Effectiveness of intravenous streptokinase on infarct size and left ventricular function in acute myocardial infarction. Prospective and randomized study. Clin Cardiol. Jul. 1987;10(7):383-92. [pmid: 3301120].
Durrer JD, Lie KI, van Capelle FJ, Durrer D. Effect of sodium nitroprusside on mortality in acute myocardial infarction. N Engl J Med. May. 13. 1982;306(19):1121-8. [pmid: 7040955].
Ebert RV. Long-term anticoagulant therapy after myocardial infarction. Final report of the Veterans Administration cooperative study. JAMA. Mar. 24. 1969;207(12):2263-7. [pmid: 4885975].
Elwood PC, Sweetnam PM. Aspirin and secondary mortality after myocardial infarction. Lancet. Dec. 22-29. 1979;2(8156-8157):1313-5. [pmid: 92668].
Ernstson S, Anari M. Cefaclor in the treatment of otitis media with effusion. Acta Otolaryngol Suppl. 1985;424:17-21. [pmid: 3865493].
Fields WS, Lemak NA, Frankowski RF, Hardy RJ. Controlled trial of aspirin in cerebral ischemia. Stroke. May-Jun. 1977;8(3):301-14. [pmid: 324036].
Flaherty JT, Becker LC, Bulkley BH, Weiss JL, Gerstenblith G, Kallman CH, et al. A randomized prospective trial of intravenous nitroglycerin in patients with acute myocardial infarction. Circulation. Sep. 1983;68(3):576-88. [pmid: 6409446].
Fletcher AP, Sherry S, Alkjaersig N, Smyrniotis FE, Jick S. The maintenance of a sustained thrombolytic state in man. II. Clinical observations on patients with myocardial infarction and other thromboembolic disorders. J Clin Invest. Jul. 1959;38(7):1111-9. [pmid: 13664786].
Giebink GS, Batalden PB, Le CT, Lassman FM, Buran DJ, Seltz AE. A controlled trial comparing three treatments for chronic otitis media with effusion. Pediatr Infect Dis J. Jan. 1990;9(1):33-40. [pmid: 2405348]. Gooch WM 3rd, Blair E, Puopolo A, Paster RZ, Schwartz RH, Miller HC, et al. Effectiveness of five days of therapy with cefuroxime axetil suspension for treatment of acute otitis media. Pediatr Infect Dis J. Feb. 1996;15(2):157-64. [pmid: 8822290].
Gottlieb SH, Achuff SC, Mellits ED, Gerstenblith G, Baughman KL, Becker L, et al. Prophylactic antiarrhythmic therapy of high-risk survivors of myocardial infarction: lower mortality at 1 month but not at 1 year. Circulation. Apr. 1987;75(4):792-9. [pmid: 3549043].
Green SM, Rothrock SG. Single-dose intramuscular ceftriaxone for acute otitis media in children. Pediatrics. Jan. 1993;91(1):23-30. [pmid: 8416502].
Hansteen V, Moinichen E, Lorentsen E, Andersen A, Strom O, Soiland K, et al. One year's treatment with propranolol after myocardial infarction: preliminary report of Norwegian multicentre trial. Br Med J (Clin Res Ed). Jan. 16. 1982;284(6310):155-60.
Harvald B, Hilden T, Lund E. Long-term anticoagulant therapy after myocardial infarction. Lancet. Sep. 29. 1962;2(7257):626-30. [pmid: 13953187].
Healy GB. Antimicrobial therapy of chronic otitis media with effusion. Int J Pediatr Otorhinolaryngol. Oct. 1984;8(1):13-7. [pmid: 6389394].
Heikinheimo R, Ahrenberg P, Honkapohja H, Iisalo E, Kallio V, Konttinen Y, et al. Fibrinolytic treatment in acute myocardial infarction. Acta Med Scand. Jan-Feb. 1971;189(1-2):7-13. [pmid: 5317798].
Hendrickse WA, Kusmiesz H, Shelton S, Nelson JD. Five vs. ten days of therapy for acute otitis media. Pediatr Infect Dis J. Jan. 1988;7(1):14-23. [pmid: 3277153].
Henry RL, Milner AD, Stokes GM. Ineffectiveness of ipratropium bromide in acute bronchiolitis. Arch Dis Child. Nov. 1983;58(11):925-6. [pmid: 6228197].
Hjalmarson A, Herlitz J, Holmberg S, Ryden L, Swedberg K, Vedin A, et al. The Goteborg metoprolol trial. Effects on mortality and morbidity in acute myocardial infarction. Circulation. Jun. 1983;67(6 Pt 2):I26-32. [pmid: 6342837].
Hoberman A, Paradise JL, Burch DJ, Valinski WA, Hedrick JA, Aronovitz GH, et al. Equivalent efficacy and reduced occurrence of diarrhea from a new formulation of amoxicillin/clavulanate potassium (Augmentin) for treatment of acute otitis media in children. Pediatr Infect Dis J. May. 1997;16(5):463-70. [pmid: 9154538]. Hockings BE, Cope GD, Clarke GM, Taylor RR. Randomized controlled trial of vasodilator therapy after myocardial infarction. Am J Cardiol. Aug. 1981;48(2):345-52. [pmid: 7023223].
Husby S, Agertoft L, Mortensen S, Pedersen S. Treatment of croup with nebulised steroid (budesonide): a double blind, placebo controlled study. Arch Dis Child. Mar. 1993;68(3):352-5. [pmid: 8466237].
Ingvarsson L, Lundgren K. Penicillin treatment of acute otitis media in children. A study of the duration of treatment. Acta Otolaryngol. Sep-Oct. 1982;94(3-4):283-7. [pmid: 6816006].
Jaffe AS, Geltman EM, Tiefenbrunn AJ, Ambos HD, Strauss HD, Sobel BE, et al. Reduction of infarct size in patients with inferior infarction with intravenous glyceryl trinitrate. A randomised study. Br Heart J. May. 1983;49(5):452-60. [pmid: 6404289].
James JA. Dexamethasone in croup. A controlled study. Am J Dis Child. May. 1969;117(5):511-6. [pmid: 4889356].
Julian DG, Prescott RJ, Jackson FS, Szekely P. Controlled trial of sotalol for one year after myocardial infarction. Lancet. May. 22. 1982;1(8282):1142-7. [pmid: 6122937].
Kafetzis DA, Astra H, Mitropoulos L. Five-day versus ten-day treatment of acute otitis media with cefprozil. Eur J Clin Microbiol Infect Dis. Apr. 1997;16(4):283-6. [pmid: 9177961].
Kari MA, Heinonen K, Ikonen RS, Koivisto M, Raivio KO. Dexamethasone treatment in preterm infants at risk for bronchopulmonary dysplasia. Arch Dis Child. May. 1993;68(5 Spec No):566-9. [pmid: 8323356].
Kennedy JW, Martin GV, Davis KB, Maynard C, Stadius M, Sheehan FH, et al. The Western Washington Intravenous Streptokinase in Acute Myocardial Infarction Randomized Trial. Circulation. Feb. 1988;77(2):345-52. [pmid: 3276409].
Khurana CM. A multicenter, randomized, open label comparison of azithromycin and amoxicillin/clavulanate in acute otitis media among children attending day care or school. Pediatr Infect Dis J. Sep. 1996;15(9 Suppl):S24-9. [pmid: 8878243].
Klassen TP, Craig WR, Moher D, Osmond MH, Pasterkamp H, Sutcliffe T, et al. Nebulized budesonide and oral dexamethasone for treatment of croup: a randomized controlled trial. JAMA. May. 27. 1998;279(20):1629-32. [pmid: 9613912]. Klassen TP, Rowe PC, Sutcliffe T, Ropp LJ, McDowell IW, Li MM. Randomized trial of salbutamol in acute bronchiolitis. J Pediatr. May. 1991;118(5):807-11. [pmid: 2019938].
Klassen TP, Watters LK, Feldman ME, Sutcliffe T, Rowe PC. The efficacy of nebulized budesonide in dexamethasone-treated outpatients with croup. Pediatrics. Apr. 1996;97(4):463-6. [pmid: 8632929].
Klein W, Pavek P, Brandt D. al. E. Resultate einer doppelblindstudie beim myokardinfarkt. Sailer S, editor. Die Fibriolysebehandlung des Akuten Myokardinfarktes. Wien. Verlag Bruder Hollinek. 1976:65-73.
Lasierra Cirujeda L, Vilades Juan E, Fernandez Clemente JJ, Dulin Verde JJ, Moreno Resina B, Munilla Garcia A, et al. [Streptokinase in myocardial infarct]. Rev Clin Esp. Feb. 28. 1977;144(4):251-7. [pmid: 847260].
Leren P. The effect of plasma cholesterol lowering diet in male survivors of myocardial infarction. A controlled clinical trial. Acta Med Scand Suppl. 1966;466:1-92. [pmid: 5228820].
Lines D, Bates M, Rechtnan A, Sammartino L. Efficacy of nebulized ipratropium bromide in acute bronchiolitis. Pediatr Rev Commun. 1992;6:161-7.
Lines D, JS K, P L. Efficacy of nebulized salbutamol in bronchiolitis. Pediatr Rev Commun. 1990;5:121-9.
Lis Y, Bennett D, Lambert G, Robson D. A preliminary double-blind study of intravenous nitroglycerin in acute myocardial infarction. Intensive Care Med. 1984;10(4):179-84. [pmid: 6432869].
Loeliger EA, Hensen A, Kroes F, van Dijk LM, Fekkes N, de Jonge H, et al. A double-blind trial of long-term anticoagulant treatment after myocardial infarction. Acta Med Scand. Nov. 1967;182(5):549-66. [pmid: 4862156].
Lowell DI, Lister G, Von Koss H, McCarthy P. Wheezing in infants: the response to epinephrine. Pediatrics. Jun. 1987;79(6):939-45. [pmid: 3295741].
Mallol J, Barrueto L, Girardi G, Munoz R, Puppo H, Ulloa V, et al. Use of nebulized bronchodilators in infants under 1 year of age: analysis of four forms of therapy. Pediatr Pulmonol. Sep-Oct. 1987;3(5):298-303. [pmid: 2959900].
Mandel EM, Rockette HE, Bluestone CD, Paradise JL, Nozza RJ. Efficacy of amoxicillin with and without decongestant-antihistamine for otitis media with effusion in children. Results of a double-blind, randomized trial. N Engl J Med. Feb. 19. 1987;316(8):432-7. [pmid: 2880294].
McLinn S. A multicenter, double blind comparison of azithromycin and amoxicillin/ clavulanate for the treatment of acute otitis media in children. Pediatr Infect Dis J. Sep. 1996;15(9 Suppl):S20-3. [pmid: 8878242].
Meistrup-Larsen KI, Sorensen H, Johnsen NJ, Thomsen J, Mygind N, Sederberg-Olsen J. Two versus seven days penicillin treatment for acute otitis media. A placebo controlled trial in children. Acta Otolaryngol. Jul-Aug. 1983;96(1-2):99-104. [pmid: 6412508].
Meuwissen OJ, Vervoorn AC, Cohen O, Jordan FL, Nelemans FA. Double blind trial of long-term anticoagulant treatment after myocardial infarction. Acta Med Scand. Nov. 1969;186(5):361-8. [pmid: 4985108].
Mohs E, Rodriguez-Solares A, Rivas E, el Hoshy Z. A comparative study of azithromycin and amoxycillin in paediatric patients with acute otitis media. J Antimicrob Chemother. Jun. 1993;31(Suppl E):73-9. [pmid: 8396100].
Moller P, Dingsor G. Otitis media with effusion: can erythromycin reduce the need for ventilating tubes?. J Laryngol Otol. Mar. 1990;104(3):200-2. [pmid: 2341774].
Morton BC, Smith FM, McKibbon TG, Nair RC, Poznanski WJ. Magnesium therapy in acute myocardial infarction. Magnesium Bulletin 1. 1981:192-94.
Nelson GI, Silke B, Ahuja RC, Hussain M, Taylor SH. Haemodynamic advantages of isosorbide dinitrate over frusemide in acute heart-failure following myocardial infarction. Lancet. Apr. 2. 1983;1(8327):730-3. [pmid: 6132082].
Ness PM, Simon TL, Cole C, Walston A. A pilot study of streptokinase therapy in acute myocardial infarction: observations on complications and relation to trial design. Am Heart J. Dec. 1974;88(6):705-12. [pmid: 4608503].
Nielsen BL, Clausen J, Nielsen JS. Can procainamide improve the prognosis of patients with ventricular arrhythmias after myocardial infarction?. Dan Med Bull. Apr. 1978;25(3):121-5. [pmid: 348411].
Olson HG, Butman SM, Piters KM, Gardin JM, Lyons KP, Jones L, et al. A randomized controlled trial of intravenous streptokinase in evolving acute myocardial infarction. Am Heart J. Jun. 1986;111(6):1021-9. [pmid: 3521245]. Pestalozza G, Cioce C, Facchini M. Azithromycin in upper respiratory tract infections: a clinical trial in children with otitis media. Scand J Infect Dis Suppl. 1992;83:22-5. [pmid: 1336892]. Peter T, Ross D, Duffield A, Luxton M, Harper R, Hunt D, et al. Effect on survival after myocardial infarction of long-term treatment with phenytoin. Br Heart J. Dec. 1978;40(12):1356-60. [pmid: 367406].
Ploussard JH. Evaluation of five days of cefaclor vs ten days of amoxicillin therapy in acute otitis media. Curr Ther Res. 1984;36:641-5.
Podoshin L, Fradis M, Ben-David Y, Faraggi D. The efficacy of oral steroids in the treatment of persistent otitis media with effusion. Arch Otolaryngol Head Neck Surg. Dec. 1990;116(12):1404-6. [pmid: 2248740].
Poliwoda H, Schneider B, Avenarius HJ. [Investigations of the clinical course of acute myocardial infarction. I. The fibrinolytic treatment of acute myocardial infarction with streptokinase (author's transl)]. Med Klin. Mar. 18. 1977;72(11):451-8. [pmid: 840117].
Principi N. Multicentre comparative study of the efficacy and safety of azithromycin compared with amoxicillin/clavulanic acid in the treatment of paediatric patients with otitis media. Eur J Clin Microbiol Infect Dis. Aug. 1995;14(8):669-76. [pmid: 8565983].
Puczynski MS, Stankiewicz JA, O'Keefe JP. Single dose amoxicillin treatment of acute otitis media. Laryngoscope. Jan. 1987;97(1):16-8. [pmid: 3796171].
Rasmussen HS, Gronbaek M, Cintin C, Balslov S, Norregard P, McNair P. One-year death rate in 270 patients with suspected acute myocardial infarction, initially treated with intravenous magnesium or placebo. Clin Cardiol. Jun. 1988;11(6):377-81. [pmid: 3396238].
Rastogi A, Akintorin SM, Bez ML, Morales P, Pildes RS. A controlled trial of dexamethasone to prevent bronchopulmonary dysplasia in surfactant-treated infants. Pediatrics. Aug. 1996;98(2 Pt 1):204-10. [pmid: 8692619].
Ritland S, Lygren T. Comparison of efficacy of 3 and 12 months' anticoagulant therapy after myocardial infarction. A controlled clinical trial. Lancet. Jan. 18. 1969;1(7586):122-4. [pmid: 4178243].
Rodriguez AF. An open study to compare azithromycin with cefaclor in the treatment of children with acute otitis media. J Antimicrob Chemother. Jun. 1996;37(Suppl C):63-9. [pmid: 8818847].
Ryden L, Arnman K, Conradson TB, Hofvendahl S, Mortensen O, Smedgard P. Prophylaxis of ventricular tachyarrhythmias with intravenous and oral tocainide in patients with and recovering from acute myocardial infarction. Am Heart J. Dec. 1980;100(6 Pt 2):1006-12. [pmid: 6778187].
Sainsous J, Bonnet JL, Serradimigni A. Intravenous streptokinase versus heparin in the acute stage of myocardial infarction. A prospective randomised trial in south-east France. Haemostasis. 1986;16(Suppl 3):140-7. [pmid: 3770540].
Salathia KS, Barber JM, McIlmoyle EL, Nicholas J, Evans AE, Elwood JH, et al. Very early intervention with metoprolol in suspected acute myocardial infarction. Eur Heart J. Mar. 1985;6(3):190-8. [pmid: 3896811].
Schaad UB. Multicentre evaluation of azithromycin in comparison with co-amoxiclav for the treatment of acute otitis media in children. J Antimicrob Chemother. Jun. 1993;31(Suppl E):81-8. [pmid: 8396101].
Schreiber TL, Miller DH, Silvasi DA, Moses JW, Borer JS. Randomized double-blind trial of intravenous streptokinase for acute myocardial infarction. Am J Cardiol. Jul. 1. 1986;58(1):47-52. [pmid: 3524182].
Schwartz RH, Rodriguez WJ. Trimethoprim-sulfamethoxazole treatment of persistent otitis media with effusion. Pediatr Infect Dis. Sep-Oct. 1982;1(5):333-5. [pmid: 7155965].
Seaman AJ, Griswold HE, Reaume RB, Ritzmann L. Long-term anticoagulant prophylaxis after myocardial infarction. N Engl J Med. Jul. 17. 1969;281(3):115-9. [pmid: 4307139].
Shechter M, Hod H, Marks N, Behar S, Kaplinsky E. Magnesium therapy and mortality in acute myocardial infarction. American Journal of Cardiology. 1990;66:271-74. [pmid: 2195862].
Shinwell ES, Karplus M, Zmora E, Reich D, Rothschild A, Blazer S, et al. Failure of early postnatal dexamethasone to prevent chronic lung disease in infants with respiratory distress syndrome. Arch Dis Child Fetal Neonatal Ed. Jan. 1996;74(1):F33-7. [pmid: 8653433].
Smith LF, Heagerty AM, Bing RF, Barnett DB. Intravenous infusion of magnesium sulphate after acute myocardial infarction: effects on arrhythmias and mortality. Int J Cardiol. Aug. 1986;12(2):175-83. [pmid: 2427458]. Sorensen OH, Friis T, Jorgensen AW, Jorgensen MB, Nissen NI. Anticoagulant treatment of acute coronary thrombosis. Acta Med Scand. Jan-Feb. 1969;185(1-2):65-72. [pmid: 4185116].
Sorensen PS, Pedersen H, Marquardsen J, Petersson H, Heltberg A, Simonsen N, et al. Acetylsalicylic acid in the prevention of stroke in patients with reversible cerebral ischemic attacks. A Danish cooperative study. Stroke. Jan-Feb. 1983;14(1):15-22. [pmid: 6337425].
Super DM, Cartelli NA, Brooks LJ, Lembo RM, Kumar ML. A prospective randomized double-blind study to evaluate the effect of dexamethasone in acute laryngotracheitis. J Pediatr. Aug. 1989;115(2):323-9. [pmid: 2754562].
Tal A, Bavilski C, Yohai D, Bearman JE, Gorodischer R, Moses SW. Dexamethasone and salbutamol in the treatment of acute wheezing in infants. Pediatrics. Jan. 1983;71(1):13-8. [pmid: 6129609].
Taylor SH, Silke B, Ebbutt A, Sutton GC, Prout BJ, Burley DM. A long-term prevention study with oxprenolol in coronary heart disease. N Engl J Med. Nov. 18. 1982;307(21):1293-301. [pmid: 6752712].
Thomsen J, Sederberg-Olsen J, Balle V, Vejlsgaard R, Stangerup SE, Bondesson G. Antibiotic treatment of children with secretory otitis media. A randomized, double-blind, placebo-controlled study. Arch Otolaryngol Head Neck Surg. Apr. 1989;115(4):447-51. [pmid: 2647105].
Varsano I, Frydman M, Amir J, Alpert G. Single intramuscular dose of ceftriaxone as compared to 7-day amoxicillin therapy for acute otitis media in children. A double-blind clinical trial. Chemotherapy. 1988;34(Suppl 1):39-46. [pmid: 3246170].
White HD, Norris RM, Brown MA, Takayama M, Maslowski A, Bass NM, et al. Effect of intravenous streptokinase on left ventricular function and early survival after acute myocardial infarction. N Engl J Med. Oct. 1. 1987;317(14):850-5. [pmid: 2888018].
Witchitz S, Kolsky H, Moisson P, Chiche P. [Streptokinase and myocardial infarction: can fibrinolysis curb necrosis (author's transl)]. Ann Cardiol Angeiol (Paris). Jan-Feb. 1977;26(1):53-6. [pmid: 855990].
Wright IS, Marple CD, Beck DF. Report of the Committee for the Evaluation of Anticoagulants in the Treatment of Coronary Thrombosis with Myocardial Infarction; a progress report on the statistical analysis of the first 800 cases studied by this committee. Am Heart J. Dec. 1948;36(6):801-15. [pmid: 18893568].
Yeh TF, Torre JA, Rastogi A, Anyebuno MA, Pildes RS. Early postnatal dexamethasone therapy in premature infants with severe respiratory distress syndrome: a double-blind, controlled study. J Pediatr. Aug. 1990;117(2 Pt 1):273-82. [pmid: 2199642].