# Appendixes

Appendix A Quality Rating Form and References of Included Trials