# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Sydne Newberry for editorial support, Brett Ewing for statistical support, Aneesa Motala for administrative support, and Ethan Balk, Nancy Berkman, Isabelle Boutron, Stephanie Chang, Issa Dahabreh, Rochelle Fu, Jonathan Sterne, Meera Viswanathan for comments on earlier drafts of the report.