# Abbreviations and Acronyms

AHRQ: Agency for Healthcare Research and Quality
CBRG: Cochrane Back Review Group
CI: Confidence Interval
EPC: Evidence-based Practice Center
ES: Effect Size
ITT: Intention-to-treat
NSAID: Non-steroidal Anti-inflammatory Drugs
OR: Odds Ratio
RCT: Randomized Controlled Trial
ROR: Ratio of the Odds Ratio