# List of Peer Reviewers

Rex Astles

Centers for Disease Control and Prevention

David Atkins

Department of Veterans Affairs

Claudia Bonnell

BlueCross BlueShield Association

Technology Evaluation Center

Joseph Boone

Battelle

Patrick Bossuyt

University of Amsterdam

Rose Campbell

Oregon Health & Sciences University

Rob Christenson

University of Maryland School of Medicine

Nananda Col

Tufts Medical School

Benjamin Djulbegovic

University of South Florida

Eileen Erinoff

ECRI Institute

Mark Helfand

Oregon Health & Sciences University

Joseph Jacobs

Abbott Molecular

Louis Jacques

Centers for Medicare & Medicaid Services

John Krolak

Centers for Disease Control and Prevention

Shalini Kulasingam

University of Minnesota

Joseph Lau

Tufts University

Kathleen Lohr

RTI International

Sally Lord

University of Sydney

Kirsten McCaffrey

University of Sydney

Diana Petitti

Arizona State University

Greg Raab

Raab & Associates, Inc.

Max Robinowitz

U.S. Food and Drug Administration

Jeff Roche

Center for Medicare & Medicaid Services

Donald Rucker

Siemens

Indy Rutks

Veterans Affairs Medical Center

Holger Schunemann

McMaster University

Jodi Segal

Johns Hopkins University

Lisa Tjosvold

University of Alberta

Frederic Wolf

University of Washington

—And members of the public