# List of Authors

Cynthia M. Balion, Ph.D.

Hamilton General Hospital and McMaster Evidence-based Practice Center

Hamilton, Ontario, CA

Eric B. Bass, M.D., M.P.H.

Johns Hopkins University School of Medicine and Johns Hopkins University Bloomberg School of Public Health

Baltimore, MD

Stephanie M. Chang, M.D., M.P.H.

Agency for Healthcare Research and Quality

Rockville, MD

Craig I. Coleman, Pharm.D.

University of Connecticut/Hartford Hospital Evidence-based Practice Center and University of Connecticut School of Pharmacy

Storrs, CT

Rongwei Fu, Ph.D.

Oregon Evidence-based Practice Center

Portland, OR

Lauren Griffith, Ph.D.

McMaster Evidence-based Practice Center

Hamilton, Ontario, CA

Katherine E. Hartmann, M.D., Ph.D.

Institute for Medicine and Public Health

Vanderbilt University

Nashville, TN

Daniel E. Jonas, M.D., M.P.H.

University of North Carolina

Chapel Hill, NC

Shalini Kulasingam, Ph.D.

University of Minnesota School of Public Health

Minneapolis, MN

William F. Lawrence, M.D., M.S.

Agency for Healthcare Research and Quality

Rockville, MD

David B. Matchar, M.D., FACP, FAHA

Duke-NUS Graduate Medical School Singapore;

Duke University Medical Center

Durham, NC

Thomas S. Rector, Ph.D.

Minneapolis Veterans Affairs Medical Center

Minneapolis, MN

Rose Relevo, M.L.I.S, M.S.

Oregon Health & Science University

Portland, OR

Crystal M. Riley, M.A.

Nanyang Technological University

Singapore

David Samson, M.S.

Blue Cross and Blue Shield Association Technology Evaluation Center

Chicago, IL

P. Lina Santaguida, B. Sc. P.T., Ph.D., M.Sc.

McMaster Evidence-based Practice Center

Hamilton, Ontario, CA

Karen M. Schoelles M.D., S.M., FACP

ECRI Institute Health Technology Assessment Group

Plymouth Meeting, PA

Jodi B. Segal, M.D., M.P.H.

Johns Hopkins University School of Medicine

Baltimore, MD

Sonal Singh, M.D., M.P.H.

Johns Hopkins University School of Medicine and Johns Hopkins University Bloomberg School of Public Health

Baltimore, MD

Brent C. Taylor, Ph.D., M.P.H.

Department of Veterans Affairs Health Care System

University of Minnesota

Minneapolis, MN

Thomas A. Trikalinos, M.D.

Tufts Evidence-based Practice Center

Boston, MA

Ben Vandermeer, M.Sc.

University of Alberta Evidence-based Practice Center

Edmonton, Alberta, CA

Tania M. Wilkins, M.S.

University of North Carolina

Chapel Hill, NC

Timothy J. Wilt, M.D., M.P.H.

Department of Veterans Affairs Health Care System

University of Minnesota

Minneapolis, MN