# AHRQ’s Evidence-Based Practice Centers

In 1997, the Agency for Health Care Policy and Research (AHCPR), now known as the Agency for Healthcare Research and Quality (AHRQ), launched its initiative to promote evidence-based practice in everyday care through establishment of the Evidence-based Practice Center (EPC) Program. The EPCs develop evidence reports and technology assessments on topics relevant to clinical and other health care organization and delivery issues;—specifically those that are common, expensive, and/or significant for the Medicare and Medicaid populations. With this program, AHRQ has become a “science partner” with private and public organizations in their efforts to improve the quality, effectiveness, and appropriateness of health care by synthesizing the evidence and facilitating the translation of evidence-based research findings. Topics are nominated by non-federal partners such as professional societies, health plans, insurers, employers, and patient groups.

The EPCs are located at:

- Blue Cross and Blue Shield Association, Technology Evaluation Center, Chicago, IL
- Duke University, Durham, NC
- ECRI Institute, Plymouth Meeting, PA
- Johns Hopkins University, Baltimore, MD
- McMaster University, Hamilton, Ontario, CA
- Oregon Health & Science University, Portland, OR
- RAND Corporation, Santa Monica, CA
- RTI International—University of North Carolina, Chapel Hill, NC
- Tufts—New England Medical Center, Boston, MA
- University of Alberta, Edmonton, Alberta, CA
- University of Connecticut, Hartford, CT
- University of Minnesota—Minneapolis VA, Minneapolis, MN
- University of Ottawa, Ottawa, CA
- Vanderbilt University, Nashville, TN

For contacts and additional information about the current participating EPCs, go to: http://www.ahrq.gov/clinic/epc/epcenters.htm.