# Preface

Effectiveness and Comparative Effectiveness Reviews, systematic reviews of existing research on the effectiveness, comparative effectiveness, and comparative harms of different medical tests, are intended to provide relevant evidence to inform real-world health care decisions for patients, providers, and policymakers. In an effort to improve the transparency, consistency, and scientific rigor of the work of the Effective Health Care (EHC) Program, the Agency for Healthcare Research and Quality (AHRQ), the Scientific Resource Center, and the Evidence-based Practice Centers (EPCs), have developed this Methods Guide for Medical Test Reviews (also referred to as the Medical Test Methods Guide). We intend it to serve as a resource for the EPCs as well as for other investigators interested in conducting systematic reviews on medical tests. We hope it will be a practical guide both for those who prepare the systematic reviews and those who use them in clinical practice, research development, and in making policy decisions].

The Methods Guide for Medical Test Reviews complements the EPC Methods Guide for Comparative Effectiveness Reviews (also referred to as the General Methods Guide), which focuses on methods to assess the effectiveness of treatments and other health care interventions. The guidance in this Medical Test Methods Guide applies the principles for the assessment of treatments to the issues and challenges entailed in assessing medical tests. It highlights particular areas where the inherently different qualities of medical tests necessitate a different or variation of the approach to systematic review compared to a review on treatments. It provides step-by-step guidance for those conducting a systematic review.

The series of chapters comprising this Medical Test Methods Guide is the result of a collaborative effort by EPC authors and external peer reviewers. In addition, leaders from AHRQ and the EPC program have collaborated with the editors of the Journal of General Internal Medicine to co-publish the Guide, which will be simultaneously posted on AHRQ’s Effective Health Care Web site at www.effectivehealthcare.ahrq.gov/reports/final.cfm and as a special supplement to the journal (Volume 27, Supplement 1).

This Medical Test Methods Guide is a living document, and will be updated as further empirical evidence develops and our understanding of better methods improves. Comments and Suggestions on the Methods Guides and the Effective Health Care Program can be made at www.effectivehealthcare.gov.

Carolyn M. Clancy, M.D.

Director, Agency for Healthcare Research and Quality

Jean Slutsky, P.A., M.S.P.H.

Director, Center for Outcomes and Evidence

Agency for Healthcare Research and Quality

Stephanie M. Chang M.D., M.P.H.

Director, EPC Program

Center for Outcomes and Evidence

Agency for Healthcare Research and Quality