# Acknowledgments

This project was funded by the Agency for Healthcare Research and Quality under contract number 290-2010-000141 (Developing and Evaluating Methods for Record Linkage and Reducing Bias in Patient Registries). The authors would like to acknowledge the University of North Carolina Lineberger Comprehensive Cancer Center and the University Cancer Research Fund for facilitating the data acquisition. They would also like to thank the Technical Expert Panel Members, and the ICISS staff and faculty collaborators, without whom this report would not be possible (http://iciss.unc.edu/team.php).