# Project Summary and Recommendations for Researchers

## Overview

Randomized controlled trials (RCTs) remain the gold standard for assessing intervention efficacy; however, RCT results often cannot be generalized due to a lack of inclusion of “real-world” combinations of interventions and heterogeneous patients.1–4 With recent advances in information technology, data, and statistical methods, there is tremendous promise in leveraging ever-growing repositories of secondary data to support comparative effectiveness and public health research. While there are many advantages to using these secondary data sources, they are often limited in scope, which in turn limits their utility in addressing important questions in a comprehensive manner. These limitations can be overcome by linking data from multiple sources such as health registries and administrative claims data.6,7,9

This report provides a conceptual framework for high-quality data linkage in the context of comparative effectiveness research (CER). It describes the infrastructure and personnel needed to navigate the linkage process, outlines the Data Use Agreement process, presents different approaches to data linkage, discusses the strengths and weaknesses of each, and makes recommendations on which approaches perform best in varying scenarios of data availability. In this report, researchers have a step-by-step instructional guide for designing new CER studies that involve linking patient registries with other secondary data sources. We also highlight considerations for researchers, data managers, information technology managers, and other stakeholders likely to be involved in the data linkage process.

## Considerations for Project Planning

### Appropriateness and Feasibility of the Project

Each data source needs to be considered carefully regarding its adequacy for the specific linkage endeavor. First and foremost, the quality and discriminatory power of each of the available linkage identifiers need to be scrutinized. Second, researchers must be confident that there is enough overlap in the two populations to merit the effort. Every linkage will result in a set of matches that will serve as a select, nonrandom, and perhaps not completely representative sample of the two disparate underlying populations. It is important that the extent and representativeness of this potential overlap be considered before beginning the process. Finally, it must be evident that the linkage will result in an enriched dataset that includes additional data elements made possible only through the linkage. Each of these considerations must be weighed together as a whole to determine whether the linkage will provide an adequate return on the investment in time and resources.

### Data Ownership and Governance

Before proposing a linkage, it must be clear that each of the respective data sources allows for the scope of the proposed work. All data owners or key stakeholders need to be contacted, and existing data-governance processes need to be understood. Rules regarding consent and any existing regulatory requirements for the data need to be clarified. The importance of these issues should not be underestimated, and the logistical, administrative, and often legal hurdles need to be anticipated and built into the cost and the timeline for the project.

### Technical Environment and Security

A secure and well-performing computing platform represents the operational backbone for conducting innovative research using large datasets. There is a fine balance between security and usability, and system performance directly influences the size and complexity of the data that can be managed and linked. Careful planning and building collaborations with teams with technical resources help decrease the cost/benefit ratio, while allowing growth in the future. As outlined in Chapter 2, a well-performing and secure research environment builds a foundation of trust with research partners and data suppliers.

### Team, Skills, and Expertise

The complexity and scope of a research project will dictate the type of team and expertise required. As scope and complexity increase, the required experience and expertise of team members narrow and deepen. Ideally, a research and data support team will already be in place before the proposal process. These individuals can provide essential insight into considerations such as feasibility, technical environment, approach, and linkage processes, all of which are identified in this report. Specific and key roles have been outlined in Chapter 2. For nearly all data linkage projects, the research team should include individuals with experience developing and evaluating linking algorithms, as well as overall expertise in population research. Other technical skills are no less essential for project success. For example, a knowledgeable data manager will be able to evaluate the appropriateness of the datasets, assess the computational feasibility of the linkage, estimate computing requirements, and develop a common data model. Information or computing technology experts can help design, run, and optimize the required technical environment and computing platform. Lastly, any large linkage project will require a conscientious and knowledgeable project manager who is experienced in the many security standards and legal documents and processes that are required to get the project off the ground and keep it moving throughout its life course.

### Cost

Several financial considerations need to be incorporated into project planning and execution for any linkage project. First, obtaining a copy of the data or purchasing a user license often comes with a hefty price. Second, the information technology (IT) systems and technical platform requirements are often significant and can be expensive to build and maintain. However, other options may be available besides building a system de novo. Renting infrastructure from another research partner or computing environment, or utilizing a third-party vendor for data linkage, may provide cost savings and synergy at an organizational level. Lastly, the technical personnel required for linking and maintaining data are often in high demand in this era of “big data” and may require high salaries for recruitment and retention.

### Identification and Evaluation of Available Linkage Keys

The quantity, quality, and discriminatory power of available identifiers will determine the feasibility and success of any linking endeavor. This information may or may not be known before data delivery but can often be estimated. Chapter 3 outlines different types of identifiers and key aspects of each, and identifies factors to consider when weighing the feasibility of a proposed linkage project. The quality, completeness, and predictive ability of each of the potential keys must be assessed separately in each respective dataset, with careful attention paid to missing, invalid, or implausible values. This effort will drive the choice of the appropriate data linkage strategy.

### Variable Cleaning, Standardization, and a Common Data Model (Normalization)

To begin cleaning and standardizing variables before linking, it is vital that the researchers obtain and review all available reference documentation (e.g., literature search, gray literature) so the research team understands the underlying intent and purpose of the data as well as the origination of the variables. These aspects of the original data directly affect the quality of the variables and drive later decisions about the appropriate linkage method. The amount of data cleaning and standardization needed depends on the quality and source of the data as well as the researcher’s question and available resources. Chapter 4 of this report outlines some of the common standardization measures required to prepare the linkage identifiers. Each key variable comes with its own idiosyncrasies, and thus a specific standardization and cleaning protocol must be developed and documented for each key. For example, decisions regarding standardization of format (e.g., dates set to “mmddyyyy”), case (e.g.., all uppercase), punctuation (e.g., remove dashes from Social Security Number [SSN]), and missing values (e.g., use a consistent value such as quotation marks [“] or periods [.] or other common values to denote missing [9999]) need to be made and documented. In some cases, secondary software or datasets (crosswalk files) may help to standardize or clean the variables (e.g., through linkage to common nicknames or synonyms).

Downstream from standardizing and cleaning identifiers, but important in preparing the data for linkage, is the development of a common data model. As the data are prepared for linkage and subsequent use, researchers need to understand, outline, define, and document the division of the data into separate subtables, as well as the relationships between tables within the linked dataset (i.e., entity relationships). This involves the development of a procedure for joining tables (e.g., assignment of a primary key) and determining whether the relationships of the individuals within these tables are one to one, one to many, many to one, or many to many. Finally, decisions regarding variables that are repeated across datasets need to be made. Elements such as sex, race, and dates are often stored in different formats and need to be standardized in the linked dataset. Furthermore, protocols for handling discrepancies (e.g., different birth dates or race categories) across data sources need to be developed and documented.

### Linkage Approach

Once the researchers have familiarized themselves with the relevant data sources and evaluated the available linkage variables, they can make an initial determination about the most appropriate data linkage strategy. Chapters 4 and 5 outline different linkage approaches and discuss the strengths and weaknesses of each approach. The first step in selecting the appropriate linkage strategy is to determine whether direct unique identifiers are available (e.g., SSNs). In scenarios in which direct unique identifiers are available, deemed to be of high quality, and nonmissing in approximately 95 percent of cases in each dataset, a deterministic approach is recommended. A one-time deterministic approach is the easiest to design, implement, and interpret. It involves a binary, “all or nothing” decisionmaking process in which record pairs are compared character for character across all identifiers. Record pairs that agree exactly on the given identifiers are classified as matches, while record pairs that disagree on even a single character are classified as nonmatches. This approach does not account for the differential discriminatory power of the identifiers or the degree to which record pairs agree. Deterministic approaches typically have high positive predictive value but often suffer from low sensitivity due to the inflexibility of the criteria.

An iterative deterministic approach, such as the well-documented Surveillance, Epidemiology and End Results (SEER)-Medicare algorithm, provides a more flexible alternative to a one-time deterministic approach. It involves an initial match on the most conservative matching criteria, followed by subsequent matches where record pairs that failed to meet the initial criteria are passed to a second, more lenient set of matching criteria. Record pairs that meet the matching criteria at any step are classified as matches, while record pairs that meet no matching criteria are classified as nonmatches. This approach is more flexible and more sensitive than the one-time deterministic approach. In scenarios in which no single unique identifier (e.g., beneficiary ID or SSN) is both available and complete but high-quality direct identifiers are available (e.g., names, dates of birth), the SEER-Medicare algorithm has demonstrated high reliability and validity.

In many cases, identifiers are available but incomplete, fraught with typographical errors, or imperfectly measured. In these scenarios, probabilistic techniques are recommended, as they have consistently outperformed deterministic techniques in earlier research. As described in Chapter 4, a probabilistic approach incorporates the differential discriminatory power of the identifiers and the degree to which two records agree into the agreement and disagreement weights for each identifier. This approach can be used to initially test and validate the discriminatory power of each available identifier. During the linking process, probabilistic methods assign an agreement weight when identifiers agree or a disagreement weight when identifiers disagree, and then derive an overall match score based on the sum of all weights. While probabilistic methods often outperform deterministic methods in information-poor scenarios, they require significantly more time, effort, and technical resources to implement.

An optimal approach that covers all scenarios, datasets, research questions, and/or situations does not exist. Often, as outlined in Chapter 5, combining probabilistic and deterministic methods can be more efficient and save computational resources. For example, a deterministic match on all direct identifiers can be executed first to identify certain matches and the remaining discordant pairs can be evaluated using probabilistic matching. The decision of which approach to use depends ultimately on the research question and the available resources.

### Evaluation and Validation of Record Linkage

Irrespective of the linkage method applied, careful evaluation of the output is needed. This begins with a manual review process. Review involves several steps, the first of which involves looking for and resolving ties in which multiple record pairs identified as matches by the algorithm have exactly the same set of values. Next, a random sample of the set of potential matches identified during the blocking phase should be reviewed to evaluate the accuracy of the algorithm and identify circumstances in which the algorithm can be refined to account for complicated cases or unforeseen patterns. Following the manual review process, the final proportion of matches should be compared to known metrics or expected (a priori) estimates. A substantial difference in the observed number of matches versus the expected number of matches is a good indication that the linkage approach needs adjustment.

### Recommendations for Reporting Results

Data linkage is a complex process that involves many decisions that may affect the validity and generalizability of the newly linked data source. We recommend that researchers who implement a data linkage to generate an analytic dataset report the results of their data linkage process in manuscripts that utilize the linked data. Specifically, we recommend that researchers use sensitivity, positive predictive value, and the f-measure to characterize the accuracy of the reported strategy. Specificity and negative predictive value, frequently reported in health services research, will be inflated because of the large number of true nonmatches and thus should not be reported. The metrics should be clearly presented for any algorithm so potential users can weigh their priorities (e.g., sensitivity over positive predictive value) and choose a strategy based on the needs of the specific project. These measures could be reported in the methods sections of manuscripts that utilize the linked data.

Following the matching process, researchers should determine whether there are any important differences in the characteristics of people who are matched and those who are unmatched. The extent to which unmatched individuals differ from matched individuals should be reported in manuscripts using the linked data. This is particularly important when researchers link existing cohorts with external data sources. If the original data source has been used extensively (for example, SEER-Medicare), then identifying any differences between the original (known) cohort and the new cohort is critical to providing transparency to the reader regarding changes in the underlying population post linkage.

### Framework for Registry-to-Claims Linkage

We provide several checklists for researchers to use for registry-to-claims linkage project planning and execution. These are conceptualized as (1) project planning, or what you need to consider before applying for funding; and (2) project execution, or what steps you need to take in order to successfully execute the research project.

### Project Planning Checklist

[ ] Appropriateness and feasibility

Correct data for research question? Will I have linkage variables, overlap in population? Adequate return on investment (ROI)? Is there enough overlap between datasets? Are additional data elements/variables obtained from completing the linkage of high quality (nonmissing, available on a majority of individuals) on the linked population [effort to link = appropriate gains in data/population]?

[ ] Data ownership and governance

Do the data sources allow for the scope of the proposed work? Are there existing data-governance processes in place? If needed, did the subjects consent to the research?

[ ] Technical environment

Do I have plans to build or leverage a technical environment compliant with security needs? Do I have enough computing power? Do I have enough storage and tools to handle big data?

[ ] Team, skills, and expertise

Do I have access to a team or existing organizational entities for all aspects of the project: data management, information confidentiality and security, linking expertise, epidemiologic expertise (re: selection bias, design, etc.)?

[ ] Cost

Do I have estimates on the cost for advanced expertise? Are the costs for the technical platform feasible over the duration of the project? Do I build or “rent”? Can I leverage aspects of the project to attract followup funding?

### Project Execution Checklist

[ ] Build data partnerships and develop Data Use Agreements

Identify stakeholders, including necessary legal, regulatory, or administrative staff. Identify regulatory/security requirements. Develop legal documents/agreements approved by all stakeholders.

[ ] Identify and recruit people with the required technical skills and expertise

Find IT systems partner, data security officer, data manager, linkage programmer, epidemiologic/population expert to help guide decisionmaking.

[ ] Identify and evaluate available identifiers/linkage keys

Determine the completeness and quality of variables needed for linkage. Evaluate missing, invalid, or unlikely values. Use this assessment to determine the appropriate data linkage strategy.

[ ] Standardize and clean linkage keys

Obtain and review ALL reference documentation available from data partners/vendors or published elsewhere (literature search, gray literature). Outline the standardization protocol for each identifier. Identify any secondary software or datasets (crosswalk files) you need to standardize or clean. Amount of cleaning required will depend on the quality and source of the data.

[ ] Develop a common data model/normalize data

Determine the entity relationships (one to many/one to one), standardize common variables across datasets (e.g., sex, race), standardize formatting (e.g., dates set to mmddyyyy), standardize case (e.g., all uppercase) and punctuation (e.g., remove dashes from SSN), determine how to handle missing values and duplicates.

[ ] Design linkage approach

By incorporating information from the previous steps, decide whether a deterministic linkage strategy is feasible by evaluating any direct identifiers for quality and completeness. Often probabilistic methods or a combined approach must be applied. Evaluate whether and how a “blocking strategy” can be used to improve efficiency and computing requirements. Be sure to incorporate necessary iterative processes, including specific steps for review/evaluation.

[ ] Evaluate/validate record linkage and reporting of linkage metrics

Conduct a manual review of match decisions. The extent and sampling of this review may vary and will be defined by the chosen linkage strategy. Compare results with target or reference populations. Calculate and report statistical measures of performance: sensitivity, positive predictive value, and f-measure.