# Linkage Feasibility—To Link or Not To Link

## Overview

In this chapter, we provide an overview of factors that researchers should consider before embarking on a data linkage project. These include:

1. Determining the feasibility of data linkage through assessing variable overlap and data quality
2. Determining the original purpose of the data and whether the terms of the original data collection prohibit the linkage
3. Determining data ownership, regulatory requirements, and limitations on use
4. Planning for data sharing and managing data security concerns
5. Ensuring that a qualified team is available to manage data security and the technical aspects of the data linkage

Because of the importance of each of these steps, researchers ideally should evaluate these concerns to the extent possible before applying for grant funding. (See Chapter 6 for a checklist with preliminary planning steps.)

## Evaluating Linkage Feasibility

A fundamental step in any linkage effort is the prospective assessment of linkage feasibility. The feasibility of a linkage project depends largely on the quantity and quality of the identifying information available in the data sources being linked.40

Identifiers, full or partial, are more or less informative depending on their discriminatory power, or number of unique values. For instance, month of birth, which has 12 unique values, is more informative than sex, which has only 2 unique values. Assuming uniform distributions, record pairs matched randomly will agree on sex 50 percent (1/2) of the time simply by chance, while record pairs matched randomly will agree on month of birth 8.3 percent (1/12) of the time. Thus, when a matched pair agrees on month of birth, it is less likely that the pair matched simply by chance and more likely that the pair matched because the records represent the same individual. In this sense, month of birth contains more information than sex. Combining identifiers further increases the number of unique values (or “pockets”), thereby decreasing the chances that two records will match by chance alone. Table 3.1 shows identifiers commonly used for record linkage.

Table 3.1 Linkage identifiers

Type of Identifier | Variable Description
Unique patient identifiers | Social Security Number Medical record number Patient/beneficiary identification number
Indirect identifiers | Name: first, last, middle, maiden, alias Dates: birth, death, diagnosis, treatment, admission, discharge Sex Geographic location: street, city, county, ZIP, State Diagnosis codes

Additional information can be gleaned from the values themselves—that is, matches on rarely occurring values are less likely to occur by chance than matches on frequently occurring values. For instance, a match on a rarely occurring surname such as Lebowski is less likely to occur by chance than a match on a frequently occurring surname such as Smith. Because of this, a match on a rarely occurring surname, compared with a match on a frequently occurring surname, increases confidence that a matched pair is a true match.

Before embarking on a linkage project, it is important to consider whether a reliable and accurate linkage is possible given the available identifiers and their discriminatory power. Potential data quality issues that cannot be known before receiving the data prevent us from knowing this for certain. For instance, every beneficiary in an administrative health plan claims database may have a Social Security Number (SSN) captured, but we cannot know ahead of time whether the SSN was entered correctly or whether it represents the given individual. For example, in a claims database, the SSN for the primary subscriber may also be used for the subscriber’s spouse and/or children. However, using prior work in information theory, researchers have the means to estimate the discriminatory power of the available identifiers and the chances of uniquely identifying an individual within a single dataset or across multiple datasets.

The discriminatory power of a given identifier or set of identifiers can be quantified using the Shannon entropy. This is calculated as the sum of the absolute value (abs) of (p*log_2_(p)), where p is the proportion of records captured by each unique value of that identifier or set of identifiers.41 Assume that you have a simple dataset of one variable (sex) and three records, one male and two females. In this scenario, the discriminatory power of the variable, sex, is equal to abs((0.33)*(log_2_*0.33)) + abs((0.67)*(log_2_*0.67)) = 0.92. Using this method, the discriminatory power of each available identifier or set of identifiers can be measured, and identifiers or sets of identifiers can be ranked from most to least discriminatory. Notice that two variables with the same number of unique values can have varying levels of discriminatory power, depending on the distribution of unique values across the records.

Additional work has led to the development of methods to assess individual identifiability or record uniqueness in a given dataset.42,43 These methods examine the frequency distributions for every possible combination of variables in the dataset. Those variables with the highest number of unique categories and those variable combinations that identify records uniquely have the best chance of accurately identifying the entity that the information represents. For the purposes of record linkage, the minimum set of variables needed to successfully link two or more datasets is that combination of variables for which each record is identified uniquely (the mean number of records in each pocket is ~1.00).42 Based on this guideline, researchers can request that each of the data vendors examine the percentage of unique records in their dataset identified by each combination of variables available for release. Variable combinations that approach the threshold of ~1.00 record per pocket in both of the datasets to be linked are likely to succeed. The ~1.00 threshold can be relaxed for researchers engaged in exploratory research. Researchers testing hypotheses are advised to adhere to the ~1.00 threshold, as false positives and false negatives will likely add bias to subsequent statistical analyses. SAS code for assessing record uniqueness in a dataset has been provided by Tiefu Shen and can be found at www.naaccr.org/Research/DataAnalysisTools.aspx under “Record Uniqueness.”

Cook and colleagues have developed a method to determine whether more sophisticated methods, such as the probabilistic techniques that will be discussed in Chapter 4, can be used to link the given data sources.44 This method determines the level of discriminatory power needed to link two records with a certain desired degree of confidence (e.g., 95%) by comparing the combined discriminatory power (assessed as weights) over all available variables with the difference between the current weight and the desired weight. This method is discussed in detail in Chapter 4. Briefly, it allows researchers to set a threshold for the discriminatory power needed to successfully match files (an information threshold) while meeting a prespecified false-positive rate. Once this information threshold is met, researchers should seek the minimum discriminatory power needed in order to avoid paying for more information than is required or unnecessarily compromising subject confidentiality.

Knowing how much discriminatory power is contained in each data source and the number of overlapping identifiers available allows the researcher to determine whether linkage is possible and informs future decisions regarding the minimal set of identifiers required to assure a high-quality linkage. However, establishing feasibility is not merely an issue of whether common variables exist, but also how much overlap exists for the data sources in both content and temporality.

Regarding content overlap, two datasets may have similar variables but very different approaches for coding data or handling missing data that could influence the quality of the data linkage. For example, assume that one dataset codes missing variables as “.” and the second dataset codes missing variables using interpolated values. While it is possible to establish a mechanical record link in this setting, the linked data may not provide useful information or, worse, may be misleading. As another example, assume that researchers are linking health plan claims data and electronic medical record data from two sources in an attempt to more fully capture information on vaccine receipt. Assume also that each data source has a variable called “VACCINE.” If one source uses a “1” to indicate a vaccine was given and another source uses a date to indicate when the vaccine was given, researchers may find that the information they hoped to gain through the linkage is fundamentally flawed and cannot be used reliably. Thus, it is important for researchers to understand not only that a variable exists, but also the metadata related to that variable, including how and why it was captured in that form.

Researchers often wish to link data sources that are refreshed, updated, or captured on different cycles. These situations with temporally changing data pose challenges due to dynamic changes in key linkage variables. For example, addresses, phone numbers, and names (e.g., of people who marry or divorce) change over time. If this information is collected at different times for different data sources, linkage success may be diminished. Additionally, temporal disparity between datasets would affect the functional data linkage utility but may be undetected in the mechanical linkage processes. For example, if record sets are linked from sources having different collection timeframes, it may be possible to correctly link the databases mechanically, but the information from the sources will not be synchronized. This could lead to misinterpretation of the joint data patterns in the merged data. Temporal disparities in data collection could also result in mechanical link failure, since the reference variables can change for any individual over fairly short time intervals. This is an important consideration both for the evaluation of variable overlap and, ultimately, for the appropriateness of inferences made using the linked data.

## Purpose and Conditions for Original Data Collection

With the evolution of data linkage techniques, researchers are now able to link multiple sources of data, including administrative health plan claims, disease registries, cohort studies, electronic medical records, financial data, and environmental data. In addition to confirming that data sources can be linked from a technical aspect, researchers must also consider ethical and legal restrictions that may limit the use of each data source that the investigator wishes to link. Two hypothetical scenarios are provided below.

Scenario 1: A researcher wishes to link State cancer registry data to administrative health plan claims data from a private health insurer to determine the impact of provider characteristics on the likelihood of a patient receiving a particular treatment. However, the insurer will not release provider information due to privacy agreements in place between the insurance company and physicians.

Scenario 2: A researcher wishes to link cohort data (previously collected in a prospective cohort study) to administrative health plan claims to evaluate the rate of sexually transmitted diseases or mental health conditions for people who participated in the cohort study. As part of the original study agreements, patients in a cohort study were told that potentially sensitive health information (e.g., treatment for sexually transmitted disease, treatment for severe mental illness) would not be collected or used as part of the research.

These hypothetical scenarios are presented to demonstrate the importance of understanding the original purposes for the data sources that the researcher hopes to use for data linkage, including limitations or conditions for data use that might affect the proposed research. Investing the time to ensure that the research objectives can be met without negative consequences for involved parties is an important step in assessing the feasibility of data linkage.

## Ownership of Data

In addition to practical and ethical considerations, described above, determining ownership of data and restrictions on data use are necessary steps for researchers who want to link data. First, identifying the “owner” of each data source will ensure that the ethical and practical considerations noted above can be addressed in the research-planning phase. Next, the researcher can begin to outline a data-governance process to ensure that the original data owners are informed of and approve the use of their data for the study in question as well as any subsequent uses of the resulting linked dataset. Generally, the data-governance plan should define:

- Who owns the data, who must grant approval for data use, and who may be granted access to the data.
- What regulatory requirements the data are subject to and what is considered “acceptable us” of the data. For example, it is possible that the data, when linked, will be subject to additional regulatory requirements not pertinent to the original unlinked data.
- Where the data will reside.
- When the various stakeholders identified above are brought in to the governance process. For example, are there requirements for original data owners to review and approve manuscripts before submission for publication in a peer-reviewed journal?
- How data use approvals will be granted and how the data will be managed and secured.
- Why the data are to be linked. What are the overarching purpose behind and goal for this linkage?

Proactive development of a data-governance process provides several benefits to the researcher. First, it will help identify before study initiation potential limits on use and publication of the data. Data vendors with little experience working with academic researchers may require more information regarding the publication process before defining data use limits. Additionally, governance definition will inform the security infrastructure development and risk-management planning discussed in Chapter 2 by identifying who will have access to the data, where data will reside, and how data will be managed. Finally, a well-defined and consistently enforced data-governance process will demonstrate to potential data owners that the researcher is committed to acting as a “good steward” of the data and building a relationship as a trusted partner to the data vendor.

The data governance process will both inform and be informed by the nature of the Data Use Agreements (DUAs) between the researcher and data partner and the applicable regulatory requirements. Proactive planning when developing the DUA will allow the researcher and data partner to identify and discuss the parameters for all potential uses of the data, including whether to allow for future linking to additional datasets and whether and when the data partner will require review and approval of resulting research products (e.g., manuscripts, abstracts). Particularly important for academic researchers, these agreements may limit publication of findings; it is important that negotiations take place early in the data-governance process to ensure that dissemination of evidence is not limited and that expectations of the original data owner and the researcher are clearly outlined.

The governance process should likewise document the nature and extent of the required Institutional Review Board (IRB) review. Large multisite studies will require a higher level of coordination among IRBs. Researchers with such studies are strongly advised to consider centralized or federated IRB structures. The vast majority of individual linking projects, however, will require review by only a single IRB. Researchers intending to produce a linked dataset for use in multiple studies, whether single or multisite, should strongly consider developing and seeking IRB approval of an “umbrella” protocol. This protocol would “cover the establishment of the research database, including information on items like data processing and governance.”45 The umbrella protocol can be amended to incorporate subsequent studies, if necessary, or subsequent studies can submit separate IRB protocols referencing the umbrella protocol.

## Data Sharing and Security Concerns

As mentioned above, a well-defined and consistently enforced data-governance process demonstrates the researcher’s desire to be a trusted partner to data vendors and others who manage large datasets. Critical to establishing and maintaining this relationship are documented processes and procedures for securing identifiable information.

Adequate planning to protect identifiable information is crucial to receiving authority to move forward with studies that otherwise may not be allowed. We provide guidance in Chapter 2 for researchers who are building their own security systems. However, not all researchers have the resources available to build such systems. In addition, not all data partners/vendors are comfortable with releasing private health information or patient-level identifiers to researchers. There are several options available to researchers who wish to link data sources but who encounter resource limitations or who are unable to negotiate successfully for access to a partner’s data. In such cases, researchers should work with data partners/vendors to determine whether hash encryption, third-party linkage, and honest brokers would satisfy security needs to allow the project to move forward.

When existing identifiers may not be released or transmitted, records can be linked effectively using identifiers encrypted before original data holder release using cryptographic hash functions.46,47 An example is the National Security Agency’s Secure Hash Algorithm v2 (SHA-2), published by the National Institute of Standards and Technology.48 SHA-2 values cannot be reverse engineered and are widely used in security applications. Applications typically include formatting the input and concatenating a prefix, one or more variables, and a postfix. Formatting these data elements identically and applying the SHA-2 algorithm using the same key will generate the same encrypted identifier in each dataset, which can be linked deterministically to other datasets that use the same formatting, data elements, and key. Actual identifiers may be stripped and the datasets still merged, allowing data partners to limit any risks related to transferring data with Protected Health Information (PHI) for research purposes.

Another option is to involve a third-party vendor or honest broker to act as an independent source for managing data. Third-party vendors typically have extensive experience managing PHI and securing data, which can be reassuring for vendors who are wary of transferring data to researchers. Honest brokers provide a “firewall” between clinical or private health data and researchers. Individuals identified as honest brokers or third-party vendors are generally selected to ensure the privacy of data and to minimize any conflicts of interest that could exist.49 One note of caution is that encryption through vendors is generally limited to exact matching. Thus, strict coordination of efforts for standardizing variables before encryption becomes critical. If the project is able to determine an effective group of variables to link on and the effective standardization of all the variables, then these algorithms can be applied at the data custodian site before encryption. A good practice would be to share SAS code with all data custodians that can run the code on the original data onsite. Then only the encrypted identifiers need to be released, and the link is done on the encrypted identifier using the deterministic approach. This will result in identical results as would be obtained from having access to the full identifiers due to the mathematical properties of these hash functions.46,47 It should be noted, however, that the difficulty of using a third party for data linkage will be in determining the linkage approach (determining the matching variables and standardization) without interacting with the data or having the opportunity to do validation checks of the match results.

## Methods for Privacy Protection in Record Linkage

In practice, you can limit exposure of Personally Identifiable Information by making available a small representative sample of the data, building the linkage algorithm iteratively with the sample, then sharing the SAS code, to then receive the full data with only the encrypted IDs.

Interacting with the identifiers to refine the linkage approach and validating the results are important to obtain high-quality record linkage. Recently, for most data operations, differential privacy has become the norm for privacy protection.50 However, privacy in record linkage is fundamentally different from most other data operations; it is difficult to tackle because the goal of record linkage is to exactly identify the real-world entity represented by the data so that the linkage can be made accurately even among twins and family members. Privacy, defined as protecting the identity of patients included in the data source, is in direct conflict with the goals of record linkage. Nonetheless, it is important to note that the information that needs most protection is the sensitive health information rather than the identity information. Removing identifying information from the sensitive health information will adequately protect the confidentiality of the health information without interfering with accurate linkage. Because of this, we must distinguish between identity disclosure (Who is this person?) and sensitive attribute disclosure (Does this person have cancer?). Identity disclosure has little potential for harm on its own. The sensitive attribute disclosure is where confidentiality can be breached.51–55

Kum and colleagues have proposed a new approach for Privacy Preserving Interactive Record Linkage (PPIRL), which defines the privacy goal as a guarantee against attribute disclosure while minimizing identity disclosure. The usability goal is to determine the minimum amount of information required while interacting with the data for high-quality record linkage and to release only that information.52,54 PPIRL is a framework that can be deployed in a record linkage project to reduce the risk of sensitive attribute disclosure by using a combination of approaches: (1) decoupling data using newly generated encrypted identifiers, or pseudonyms (discussed in Chapter 2); (2) adding fake data to block against group disclosure (i.e., by temporarily adding fake people without cancer to the registry so that one cannot infer with confidence that an identified subject has cancer merely by their being on the registry); and (3) restricting information in any variable by limiting it to what is needed (e.g., using Soundex of name).

Selection of privacy protection methods in record linkage is a separate decision to the approach selected for doing the record linkage (deterministic or probabilistic). One-way hash encryption can support any deterministic methods and give identical results. PPIRL can support both deterministic and probabilistic methods and allows for interaction with the data for iteratively refining the linkage method and validating the results. Thus, results will not differ from those from other described methods for implementing the data linkage methods selected. However, PPIRL may provide better protection of patient privacy in settings where confidentiality concerns are of paramount importance.

## Building the Team

A “team science” approach is required to successfully develop and execute a linking project. This involves multidisciplinary collaborations in which experts from different fields share insights, perspectives, and tools from their respective disciplines. These individuals need to be technical experts but also must be able to bridge technical and disciplinary gaps and communicate effectively across the team to achieve a cohesive solution.56 However, true “team science” must be “transdisciplinary,” defined as integrating the disciplines within the research framework in a way that moves the project beyond what would be achieved by any of the individual disciplines alone.57,58 Linking data effectively requires identifying individuals from diverse fields, including population science, information science and technology, [bio]statistics/analytics, and regulatory/legal project management. It is important to identify and recruit potential team members in the early stages of the linkage project because each will have important and specific insight regarding feasibility.