# Research Environment

## Overview

A foundational element of any research project is the research program environment. In the context of comparative effectiveness research (CER) using linked data, a secure and well-performing environment is important for several reasons, including that it helps build and assure trust between researchers and the providers of sensitive data, be they patients, registry administrators, insurance claim administrators, or others. If data providers are confident that a research partner has strong administrative and technical security systems and takes data security seriously at a programmatic level, they will be more confident in providing sensitive data to the researchers, including data with unique identifiers. As we describe in Chapters 4 and 5 of this report, linkage quality is typically much stronger when unique identifiers are available. Therefore, a secure research environment and capable information technology support can directly influence the quality of the research data obtained and, by extension, research results. With faith in the integrity and security of the research environment, data providers may also be more likely to provide other unique data that can be important to driving truly innovative research.

A secure and well-performing environment is also important in that system performance and security controls can directly influence the scope of the research project, including the size and complexity of the data that can be managed and linked to support the project. Often, as the scope and complexity of research projects increase and the data volume grows, computing environments are challenged to scale up to ensure seamless operations.

This chapter describes key considerations concerning the research environment, including the technical platform and security considerations, to guide researchers as they seek to develop or optimize their systems for CER projects using large volumes of data such as linked registry and administrative claims data.

## Computing Systems and the Balance Between Security and Usability

As shown in Figure 2.1, security and usability often stand on opposite ends of a spectrum. The tradeoff for having a highly secure system is decreased accessibility and practical usability, whereas systems that are highly accessible often face greater challenges in assuring data security. Understanding the scope of the research project and the needs of the researcher or research team is important to specifying a system configuration that meets the needs of the project and balances security with usability. For example, a single researcher with a small research project of limited scope will likely have different needs for a computing environment compared with a large decentralized research team undertaking a multiyear research study using national data.

Figure 2.1 Security versus usability

Figure 2.1: This figure depicts the concepts of security and usability on separate ends of a spectrum.

We present three different computing system scenarios to help researchers identify where on the spectrum their program may fall. While this discussion does not take into account the number of users, it is important to note that the cost of large systems varies greatly depending on existing infrastructures and purchasing prices of solutions offered by various vendors.

### Desktop Computer: High Security, Low Usability, Low Cost

In this environment, the user accesses all data on a dedicated desktop computer located in a dedicated and constantly locked office with limited network access.

- Security: The risks of theft and network attacks are reduced to a minimum.
- Usability: Multiple users will never be able to access the data concurrently.

### Central Server: Medium Security, Medium Usability, Moderate Cost

This environment allows multiple users to connect remotely through a secure command line (e.g., through a secure protocol such as SSH) to a central computing server housing all the data and tools.

- Security: The risk increases while gaining access to information over a network. Controlling individual users’ access to information creates new administrative challenges.
- Usability: Multiple users can collaborate on a central system. Computing jobs can be submitted in the background and the progress can be checked from remote locations.

### Virtual Remote Desktops: High Security, High Usability, High Cost

This environment allows multiple users to connect remotely to virtualized desktops over the Internet from laptops or desktop computers to access shared data and tools.

- Security: Since the accessing computers supply only monitor, keyboard, and mouse, the data never leave the server environment. Even secure printing to dedicated printers is possible to control paper output.
- Usability: Each user connects to a virtual computer in the central environment. All tools are housed on the server but accessed through existing desktops.

## Building the Technical Platform

Regardless of the selected technologies, the number of users, or security requirements, the technical platform can be disassembled into various components (Figure 2.2). Defining the requirements for the individual components creates a meaningful information technology plan.

Figure 2.2 Component architecture

Figure 2.2: Component architecture. This figure illustrates sample components of a technical platform. The computing system encompasses storage and processing components. The access component bridges the computing system and users. The security component encompasses both users and the computing system.

### Securing the Platform

Most regulatory security frameworks, such as the Health Information Portability and Accountability Act (HIPAA) and Federal Information Security Management Act (FISMA), focus on controlling the confidentiality, integrity, and availability of information. The efforts to implement administrative, physical, and technical safeguards tend to scale up as the system complexity increases. Regulatory requirements and risk assessments will strongly affect the technical implementations.

### Users Accessing Platform

To support a wide range of innovative research on complex linked data resources, the experience and focus of team members narrow and deepen. Work is divided among individuals to cover areas such as data management, data linking, cohort discovery, advanced modeling, and more. Complex research projects depend on the seamless integration and collaboration of the various users and the use of their preferred tools. By defining the user profiles and job responsibilities, the main usability properties of the expected environment are established. Examples of typical roles within complex project teams include the following.

Role: Data Manager. The data manager takes care of the data. This might include importing new data, conversion of file formats, preparation and receipt of data carriers (storage devices), archiving obsolete data, and granting access to data.

Role: Data Linking. The linking expert is responsible for linking data sources. This might include cleaning linking variables, building linking methods, and cohort discovery (e.g., selection of patients meeting specific study-inclusion criteria), resulting in datasets for various research projects.

Role: Analyst/Statistician. The statistician is responsible for all modeling aspects of a research study. These might include creating analytic cohorts for study questions (using previously linked deidentified data), preparing data for modeling, and analyzing data to meet project objectives.

### Gaining Access to Platform

Access management controls how users gain access to the system and data. An existing organization might have a central user-management process that establishes authentication with a simple username/password combination. More advanced two-factor authentication methods ensure that a compromised password alone does not convey access to the system. Biometric authentication (e.g., fingerprint reader) verifies the identity of the intended user. Examples of commonly used authentication methods and their pros and cons are provided in Appendix 2.1.

### Processing Power of Platform

The processing power of the computing system directly affects the time it takes to manipulate the data. As linking processes touch the same information repeatedly, tuning parameters to optimize the performance of hardware and software will reduce the run times. For considerations for hardware performance, see Appendix 2.1.

It is important to understand that the researcher’s network has an impact on data flow. The network can quickly become the bottleneck for moving data, resulting in an exceptionally slow response. In an optimized setup, the connection between data and processing components is a dedicated Gigabit (1,000Mbps) network or even fiber optics. Any components between the processing and storage, such as firewalls, network switches, or routers, will reduce information flow. In a setup in which the data are stored on hard drives directly attached to the processing system, network performance will have a limited impact on data flow.

### Data Storage Platform

The storage performance directly affects the time it takes to perform data tasks. For example, tasks such as cleaning and standardizing data, combining data sources, or performing exploratory analyses of linked data sources are storage-intensive activities. The main technical characteristics of the storage platform are size and speed. A storage device is attached using a specific technology, such as Serial Advance Technology Attachment (SATA), Serial Attached Small Computer System Interface (Serial SCSI or SAS), Universal Serial Bus (USB), or Storage Area Network (SAN). Various vendors sell enterprise storage solutions encapsulating multiple storage devices in a single appliance.

Storage Size. When purchasing data carriers, it is important to understand that physical data size and actual available data size will greatly vary depending on the installation. Methods used to prevent data loss, such as Redundant Array of Independent Disks (RAID), might require as much as twice the amount of physical space as required for storing the physical data. The file system used to store data also affects available data size. A data carrier is divided into blocks like a blank book with many pages. The size of the data block is fixed for the entire file system. As an example, if the block size is 1,024 characters (or bytes) and a file of 1,500 characters is saved, it will consume 2,048 physical bytes on the data carrier. Since the partially used blocks cannot be used for other files, these bytes are “lost.”

Storage Speed. Storage devices have two speed-related properties: (1) the time it takes to find the data on the carrier (referred to as seek time and measured in milliseconds) and (2) the continuous read/write performance. The seek time depends mainly on how fast the disk is spinning. Common rotation speeds are 5,400, 7,200, 10,000, and 15,000 revolutions per minute (RPM). In the case of a solid state disk (SSD), the seek time will be extremely low, as there are no moving parts. The continuous read/write performance depends not only on how fast the disk is spinning, but also on how the disk is attached to the processing system.

A well-performing storage system can read/write information at rates of 100MB/s or more. A disk spinning at 5,400 or 7,200 RPM, as delivered in standard laptops or desktops, generally cannot achieve this. In comparison, an SSD attached over SATA can easily reach read/write rates of 500MB/s or more. To optimize cost, a computing system can be outfitted with slower/cheaper storage for archiving in combination with fast analytic storage to support powerful processing.

## Securing the Research Environment

### Overview

Federal and State laws have mandated several sets of regulations, each intended to address one or more of the following objectives:

- Confidentiality: Preserving authorized restrictions on information access and disclosure, including means for protecting personal privacy and proprietary information
- Integrity: Guarding against improper information modification or destruction; includes ensuring information nonrepudiation and authenticity
- Availability: Ensuring reliable and timely access to information

### Regulatory Requirements

The research environment must comply with applicable laws to protect the hosted information. Because HIPAA governs health information collected by covered entities mainly during health encounters, alternative research datasets might require compliance with other contractual requirements or State regulations. Researchers should consult with a regulatory expert as early as possible to ensure that they understand the scope of all applicable laws.

Regulatory requirements generally describe what must be controlled and leave it up to the research team to define how to reach the required controls by implementing adequate policies and procedures. Some State-level privacy laws may govern even self-collected information. In the following sections, we describe a sample of regulatory requirements that might be applicable to researchers working with sensitive health information.

Federal Information Security Management Act of 2002. FISMA defines a mandatory framework for managing information security for all information systems used or operated by a U.S. Federal Government agency or by a contractor or other organization on behalf of a Federal agency. It requires the development, documentation, and implementation of an information security program. The National Institute for Standards and Technology (NIST) standards and guidelines (Special Publications 800 series) and Federal Information Processing Standards (FIPS) publications further define the framework of the program.

Health Information Portability and Accountability Act. The U.S. Congress created HIPAA in 1996. Security standards establishing requirements to safeguard Protected Health Information (PHI), both paper and electronic (ePHI), were issued as part of HIPAA in April 2003. The security requirements specifically address administrative, physical, and technical safeguards meant to ensure that patient health records and Personally Identifiable Information (PII) remain as secure as possible.

State Security-Breach Laws. Forty-six States, the District of Columbia, and multiple U.S. territories (Guam, Puerto Rico, and the Virgin Islands) have enacted privacy-breach notification laws. While these laws can vary from State to State, they generally follow a similar framework. This framework defines “sensitive data,” sets out requirements for triggering the breach-notification process, identifies actors and roles in the notification process, defines to whom the law applies, and describes those cases under which certain parties and/or information may be exempt from notification requirements (www.fas.org/sgp/crs/misc/R42475.pdf). Researchers are responsible for understanding their responsibilities under the relevant State breach-notification legislation and should consult legislative resources such as the National Conference of State Legislatures for regulatory text (www.ncsl.org).

### Identifying Sensitive Data

Sensitive data are the information protected by regulatory requirements. The definition of sensitive data varies widely between laws. In some cases, the scope of a Data Use Agreement (DUA) could even require aggregation or define minimum cell sizes. In the following section, we provide a summary of regulatory definitions per FISMA, HIPAA, and State security-breach laws.

Personally Identifiable Information, FISMA. As used in information security, PII is any information maintained by an agency that can be linked to an individual. This includes (1) any information (e.g., name, Social Security Number, date and place of birth, mother’s maiden name, or biometric records) that can be used to distinguish or trace an individual’s identity and (2) any other information (e.g., medical, educational, financial, and employment information) that is linked or linkable to an individual. Examples of PII include, but are not limited to—

- Name, such as full name, maiden name, mother’s maiden name, or alias
- Personal identification number, such as Social Security Number, passport number, driver’s license number, taxpayer identification number, or financial account or credit card number
- Address information, such as street address or email address
- Personal characteristics, including photographic image (especially of face or other identifying characteristic), fingerprints, handwriting, or other biometric data (e.g., retina scan, voice signature, facial geometry)

Protected Health Information, HIPAA. The HIPAA Privacy Rule protects all “individually identifiable health information” held or transmitted by a covered entity or its business associate in any form or media, whether electronic, paper, or oral. The Privacy Rule calls this information Protected Health Information, or PHI.

Under HIPAA, individually identifiable health information is information, including demographic data, that relates to any of the following:

- The individual’s past, present, or future physical or mental health condition
- The provision of health care to the individual
- The past, present, or future payment for the provision of health care to the individual
- Information that identifies the individual or for which there is a reasonable basis to believe it can be used to identify the individual

Individually identifiable health information includes many common identifiers (e.g., name, address, birth date, Social Security Number). The Privacy Rule excludes from PHI employment records that a covered entity maintains in its capacity as an employer, and educational and certain other records subject to or defined in the Family Educational Rights and Privacy Act, 20 U.S.C. §1232g.

Electronic Protected Health Information, HIPAA. The HIPAA Security Rule protects a subset of information covered by the Privacy Rule, which is all individually identifiable health information a covered entity creates, receives, maintains, or transmits in electronic form. The Security Rule calls this information electronic Protected Health Information, or ePHI. The Security Rule does not apply to PHI transmitted orally or in writing.

Limited Datasets, HIPAA. HIPAA also has a provision for Limited Datasets (LDSs) from which most but not all potentially identifying information has been removed. Elements in an LDS are often necessary for research; however, Direct Identifiers, a subset of PHI defined by HIPAA §164.514(e)(2), must be removed. The Direct Identifiers include—

- Name
- Postal address information other than town or city, State, and ZIP Code
- Telephone numbers
- Fax numbers
- Electronic mail addresses
- Social Security Numbers
- Medical record numbers
- Health plan beneficiary numbers
- Account numbers
- Certificate/license numbers
- Vehicle identifiers and serial numbers, including license plate numbers
- Device identifiers and serial numbers
- Web Universal Resource Locators (URLs)
- Internet Protocol (IP) addresses
- Biometric identifiers, including finger and voice prints
- Full-face photographic images and any comparable images

LDSs can include the following PHI:

- Date of birth
- Date of death
- Dates of service
- Town or city
- State
- ZIP Code

Personal Information, State Security-Breach Laws. Researchers should review applicable State legislation for definitions of Personal Information. Generally, these definitions do not vary substantially from State to State and are very similar to Federal definitions. For example, the North Carolina State Security-Breach Laws (North Carolina General Statute §75-65) define Personal Information as a person’s first name or first initial and last name in combination with any of the following identifying information:

- Social Security Number or employer taxpayer identification numbers
- Driver’s license, State identification card, or passport numbers
- Checking account numbers
- Savings account numbers
- Credit card numbers
- Debit card numbers
- Personal Identification Number (PIN)
- Electronic identification numbers, electronic mail names or addresses, Internet account numbers, or Internet identification names
- Digital signatures
- Any other numbers or information that can be used to access a person’s financial resources
- Biometric data
- Fingerprints
- Passwords
- Parent’s legal surname before marriage

### Summary of Protected Information

The research team may find it useful to summarize in matrix form the protected information types identified by applicable regulatory requirements. This matrix will help the research team identify information in datasets and assess the policies and procedures that might apply to a specific work task. Table 2.1 shows an example of one such matrix.

Table 2.1 Example of matrix summarizing protected information types

Identifying Information | Sensitive Data Type
Identifying Information | Personal Information | Direct Identifiers
Name (full name/maiden name/mother’s maiden name/alias) | X | X
Address information | | X
Telephone/fax information | | X
Personal IDs (SSN/taxpayer ID/driver’s license number/State ID/passport number/birth date/certification or license numbers) | X | X
Financial IDs (checking/savings account numbers/PINs/credit card numbers) | X | X
Electronic IDs (email name/address/Internet account numbers/Internet ID/ passwords) | X | X
Personal characteristics (digital signatures/biometric data/fingerprints/handwriting/full-face images) | X | X
Health care data/provisions/payment/beneficiary information (past, present, or future) | | X
Employment information | | X
Device IDs/serial numbers | | X
Vehicle IDs | | X

PIN = Personal Identification Number; SSN = Social Security Number.

### Building and Implementing a Security Plan

Meeting applicable regulatory requirements requires thoughtful planning and management. While it is tempting to think of information security in terms of technological controls, successful security management requires people, processes, and technology in equal proportion. An overarching security management plan addresses how people, processes, and technology will be leveraged to maintain the confidentiality, integrity, and availability of sensitive data within the bounds set by applicable regulatory requirements.

While development of the security management plan is an iterative process, with sections added or refined as planning activities proceed, the document will ultimately address the following:

- Security laws and regulations describe those regulatory requirements applicable to the research team, as discussed previously.
- Major functions list those functions the security plan is intended to accomplish.
- Scope lists those sensitive data types the security program is intended to address.
- Roles and responsibilities describe roles that will be held by members of the organization and their responsibilities vis-à-vis information security.
- Management commitment represents an official statement on the part of the applicable management body in support of the processes and procedures documented within the security plan.
- FISMA security categorization and impact level define the FISMA category assigned to the data and information systems covered by the security plan. This section is applicable only to those systems subject to FISMA.
- Compliance and entity coordination describe which roles are responsible for ensuring organizational compliance with the security plan and which roles are responsible for coordinating security activities among relevant entities external to the research team (e.g., data centers, overarching security offices).
- Implementation and governing plans describe, at a high level, the number and content of all security subplans, defining the processes and procedures for—
  – Security documentation control
  – Risk management (described in further detail below)
  – Workforce security
  – Access management
  – Security training
  – Incident reporting
  – Contingency planning
  – Security assessment
  – Facility access
  – Workstation access
  – Devices and removable media
  – Data integrity
  – Authentication
  – Network security
  – System activity review/audit

At the outset of security planning, the research team should be able to define the security laws and regulations, major functions, and scope sections. Roles and responsibilities, management commitment, entity coordination, and FISMA categorization (if applicable) can be defined further through stakeholder meetings. The processes and procedures documented in the subplans will be developed as part of the risk-management process described below.

### Workforce Training

A training plan defines working procedures, emergency and incident management, sanction policies, policies and procedures on how to inform members of the workforce about their roles and responsibilities, and other relevant procedures. Many large research environments might be able to leverage existing training modules. These might include training on HIPAA, research ethics, basic computer and network use, and basic human resources policies. Keeping the retraining on an annual basis is advisable.

## Managing Risks

Research teams must first understand regulatory requirements, then select and implement adequate security controls to meet these requirements and to mitigate risks posed to the security of the organization’s information systems and data. Often, discussions of information security mistakenly emphasize specific technical safeguards. An emphasis on risk management, however, properly defines technical solutions as the means by which organizational risks are controlled. Risk management, therefore, drives information security planning. A comprehensive risk-management program not only allows data custodians to identify risks posed to their data, but also provides a framework for selection of functional and technical security controls.

Data custodians subject to FISMA requirements should consult NIST guidance for implementing a FISMA-compliant life-cycle program, which includes detailed volumes of guidance and controls. We illustrate a more general risk-management framework in Figure 2.3. This framework envisions risk management as a continuous cycle of assessing, addressing, and monitoring organizational risk to ensure the confidentiality, integrity, and availability of information systems.

Figure 2.3 Risk-management cycle

Figure 2.3: Risk management cycle. This figure illustrates the components of the risk management cycle in order: (1) identify and assess, (2) plan, (3) implement, and (4) monitor.

### Identifying and Assessing Risk

Risk identification is conducted on any technology, process, and procedure within the scope of the environment. Risk identification is, simply put, the process of identifying and documenting potential threats to the research team’s information and information systems. Risk identification can be conducted in a variety of ways, including brainstorming sessions, documentation reviews, assumptions analysis, cause and effect diagramming, strengths/weaknesses/opportunities/threats (SWOT) analysis, and expert consultation. Inclusion of an independent third party, be it an outside consultant or even representatives from a separate group within the research team, will provide an external point of view invaluable in fully defining the spectrum of potential adverse events. Regardless of the method used, this process must clearly identify and document the source of the risk and the impact of the risk should it be realized.

Assess identified risks along two primary dimensions: probability of occurrence and criticality of impact. Actions and mitigations planned in the next phase of the risk-management cycle will be based largely on each risk’s score as assessed during this phase.

Risk scores evaluate the combination of the probability and impact of a security breach/incident. Higher scores represent higher security risks. Lower scores represent reduced security risks. Table 2.2 provides an example of how to plot and assess the severity of a security breach/incident (criticality of impact) and the likelihood of occurrence of an event.

Table 2.2 Example of risk scores

| | Criticality of Impact
| | Low | Medium | High
Probability of Occurrence | High | 3 | 6 | 9
Probability of Occurrence | Medium | 2 | 4 | 6
Probability of Occurrence | Low | 1 | 2 | 3

Examples of impact:

Loss of data

Loss of public confidence

Potential lawsuit

Multiplier effect

Examples of occurrence:

Frequency of information access

Number of users

Size of dataset

### Tracking Risks

The risk register is the collection of all identified risks, their assessed impact and probability, and possible actions/mitigations. Both HIPAA and FISMA mandate the analysis of risk and a record thereof. Table 2.3 is an example of a generic risk register.

Table 2.3 Example of generic risk register

Risk ID# | Score | Title | Description | Impact | Impact Score | Probability Score | Action
R001 | 6 | Equipment stolen from office site | An individual gains access to office and removes electronic equipment. | Leak of data; through loss of computers, access to secure systems might be compromised. | High | Med | Lock building, encrypt data, alarm system
R002 | 3 | Network access | An individual gains access to the network within the organization. | Leak of data; stolen passwords; computers connected to network are subject to hack or sniff attacks. | High | Low | Network firewalls, internal switched network, virus software, secure wireless
R003 | 6 | Remote support | Support staff member gains access to an organizational computer for remote support purposes. | Leak of data; open connections to protected systems and open windows displaying PHI are visible to support individual. | Med | High | Configure to no auto desktop sharing; close applications with PHI
R004 | 6 | Computer crash or upgrade | A computer used to access PHI stops working or is upgraded. | Leak of data; leak of passwords; old hard drive might get reused; warranty traded or sold. | High | Med | Disk encryption; disposition policy; no saving of passwords; use password management software
R005 | 2 | Lack of DUA understanding | DUA limitations might be misinterpreted. | Violation of contract; misuse of data; leak of data. | Low | Med | Governance; DUA clarification and training
R006 | 2 | Unauthorized staff gains access to data | Staff, students, collaborators, reviewers gain access to data protected by DUA. | Violation of contract; misuse of data; leak of data. | Low | Med | Administrative safeguards, training
R007 | 6 | Data emailed for review | Protected data are shared through email; electronic documents within the intent of review. | Leak of data; violation of contract; information is no longer housed in secure environments. | Med | High | Secure email; training in email use; secure drop box
R008 | 2 | Data emailed to incorrect individual | An email with protected information is sent to an unintended recipient. | Leak of data. | Low | Med | Email training; secure drop box

DUA = Data Use Agreement; Med = medium; PHI = Protected Health Information.

### Planning Risk Responses

Once risks have been identified, assessed, and documented in the risk register, data custodians and other stakeholders can plan appropriate methods of dealing with each risk. Risk responses can be divided into four categories: avoidance, acceptance, transfer, and mitigation.

- Risk avoidance occurs when a research team takes the necessary actions to reduce the likelihood of risk realization to close to (if not exactly) zero. Generally, risk avoidance is the most desirable method of dealing with risks; however, it is often cost prohibitive or simply infeasible to avoid all risks.
- Risk acceptance occurs when a research team chooses to accept the consequences of a risk should it be realized. Risk acceptance is generally recommended when the impact of a risk is small or when the probability of occurrence is significantly lower than the cost to avoid, transfer, or mitigate. Each research team must define its own criteria for what constitutes an “acceptable” risk.
- Risk transfer occurs when a research team passes the impact of risk realization on to another party. The most common form of risk transfer is insurance. Risk transfer is feasible only when the impact can be clearly measured and addressed by the third party.
- Risk mitigation occurs when a research team takes steps to reduce the probability or impact of risk realization. Risks that cannot be avoided, accepted, or transferred must be mitigated.

After a research team decides whether to avoid, accept, transfer, or mitigate a risk, it must determine the necessary steps to do so. At this juncture, the research team will identify the necessary and appropriate technical controls to either avoid or mitigate certain risks. Actions identified in this phase must also be documented in the risk register.

### Implementing Risk Responses

During the implementation phase, the research team develops and deploys the technical controls identified in the planning phase. Just as importantly, the research team must also document the controls selected, develop all necessary records, and train stakeholders accordingly. Users must understand not only how to use any security controls implemented but also the “rules of behavior” for maintaining a secure environment. Technical controls alone are not sufficient to create a fully secure environment; users and other stakeholders must foster and maintain a culture of security.

### Monitoring Risks

Risk management is an ongoing cyclical process. The research team must periodically reassess the environment for new or changing risks, which in turn must be identified, assessed, and addressed through planning and action. Thoughtful and frequent monitoring of risk allows a research team to adapt more easily to changes, both expected and unexpected, without compromising information security.

## Conclusions

A research environment incorporating a secure and well-performing computing platform represents the operational backbone for conducting innovative research using complex linked data sources. Securing and safeguarding the information not only meets legal and regulatory requirements, but also builds needed trust among stakeholders. Data providers will be more open to providing access to their information, researchers will be confident in accessing sensitive data, and programmers and analysts will operate effectively in a standardized environment with consistent application of technologies and tools. The technical implementation, combining performance and storage, will enable complex data management, as described in Chapter 3. Supported by the leadership, successfully implemented security policies and procedures fit seamlessly into daily workflows, reducing and mitigating potential risks. The environment is now ready to support research and to receive even the most sensitive data.

## Appendix 2.1 Procedures and Processes To Enhance Data Security

### Moving Sensitive Data Using CDs or DVDs

Perform the following steps to create and transport sensitive data using CDs or DVDs. This procedure can be adapted for electronic transfer using a protocol such as the secure file transfer protocol (SFTP).

1. Create a new media number and add it to a data carrier list tracking all movable media containing sensitive data.
2. Create a local folder with the media number as the name.
3. Assemble all the data in the created folder.
4. Generate an encryption key using a GUID (globally unique identifier) tool such as that found at www.guidgenerator.com/ and print it on a document along with the media number.
5. Create an archive using a PGP (http://en.wikipedia.org/wiki/Pretty_Good_Privacy) encryption tool with all the contents of the folder, using the GUID as the encryption key.
6. After testing the self-extracting archive, use a file-shredding tool (www.fileshredder.org/) to remove the folder with the data.
7. Burn the archive onto a data CD or DVD labeled with the media number.
8. You can now mail the data carrier, and fax or email the encryption key separately to the receiving party.

### Guidelines for Storage and Destruction of Movable Media

- Store movable media in a safe, separated from the encryption keys.
- Destroy damaged and/or retired media, including hard disks, by shredding.
- Update movable media records for every media item that is disposed of or destroyed.
- Shred any printed material at location or use a secure document disposal service.

### Decoupling and Mapping Data

Figure 2.4 describes a process for adding data sources to the research data environment, removing direct identifiers, and creating a merged dataset with elements regarding the individuals’ health status or health services utilization. In the context described below, we retain Protected Health Information (PHI) within the original data files but limit access (a process known as decoupling). When PHI is destroyed following the data linkage, this is known as deidentification. We use the terms deidentified and decoupled interchangeably in this report as we discuss data security and staging, but readers should understand the differences represented by the terminology.

Figure 2.4 Process for creating a merged dataset

Figure 2.4: Process for creating a merged dataset. This figure describes the process of creating a merged data set, beginning with a new data source from which data files with no direct identifiers or finder files with direct identifiers can be derived. Finder files can be mapped to finder files from other sources, such as a patient registry, to create a crosswalk. Once direct identifiers are removed from the crosswalk, researchers have a de-identified merged dataset for use in analysis.

Data file: This file contains raw data such as claims, diagnoses, and treatment. Individuals cannot be directly identified in these data.

Finder file: The finder files contain direct identifiers of individuals.

Mapping process: Using a mapping method, the individuals in the finder files are matched.

Crosswalk: The crosswalk identifies matching records for each individual and possible duplicates. A new unique identifier (ID) is assigned for each true identified research subject.

Removal of direct identifiers: Using the crosswalk and the data file, a new file is generated by replacing the source identifiers with the new IDs.

Merged dataset: Information about an individual can now be accessed across data sources and deidentified datasets using the new IDs.

### Physical Separation of Data Using Storage Architecture

In the computing environment, data are separated physically into the three storage areas, as shown in Figure 2.5.

Figure 2.5 Physical storage areas

Figure 2.5: Physical storage areas. This figure illustrates the relationship between direct identifier storage, de-identified storage, and project storage.

Direct identifier storage: Raw data including direct identifiers are secured in a highly restricted part of the system. The direct identifier space is accessible only through very restrictive access-management controls. All work on data linking and removal of direct identifiers is performed in this environment. Only a limited set of specifically trained, authorized individuals work in this environment.

Deidentified storage: The deidentified space contains deidentified master datasets from each source. This storage might be accessible to authorized users in read-only mode. Research datasets are extracted, or “cut,” from these master files.

Project storage: Individual programmers access this space for projects. Institutional Review Boards and Data Use Agreements control the access to master datasets and datasets for projects.

### Examples of Common Authentication Methods

Simple User Account. A user authenticates with username and password.

- Pros: This is a quick and simple way to access a system.
- Cons: Once the username and password are known, any individual can gain access.

Two-Factor Authentication. A user authenticates with username, password, and Personal Identification Number (PIN) (e.g., RSA secure ID).

- Pros: A changing PIN provides a second factor in addition to logging in with the username and password. An authentication is not possible without the device.
- Cons: The PIN verification is costly and, depending on the implementation, requires that the computing environment have access to the system verifying the PIN.

Biometric Authentication. A user authenticates with username, password, and (for example) a fingerprint.

- Pros: The additional biometric verification requires the account holder to be present at the time of authentication.
- Cons: Managing biometric information requires custom software installations on the client system.

### Performance Considerations for Computer Hardware

Fine-tuning the three hardware components of memory, central processing unit (CPU), and bus speed is essential for the actual processing power. Random access memory (RAM) can be added after a purchase, but changes to the CPU or bus speeds are complicated and impractical. The bus speed represents how fast information can be moved between the CPU and the memory, and from and to the attached storage. When purchasing a system, you should purchase the highest affordable CPU/bus speed combination while leaving space to add memory later.

Central Processing Unit. Performance of a CPU is affected by (a) sockets (i.e., actual number of CPUs); (b) cores and threads (i.e., how instructions can be processed in parallel); and (c) clock (i.e., a number in GHz representing how many instructions are processed per second).

Random Access Memory. Selecting memory is dependent on the supported architecture of the motherboard. Manufacturers generally advise on what type of memory is supported and best for optimized performance. The product description of memory often includes physical and performance parameters. For example “240-Pin DDR3 1600” represents memory that has 240 pins connecting it to the motherboard and supports a 1600MHz clock.

Bus Speed. Depending on the architecture, there are multiple bus speeds affecting data throughput between storage, memory, and CPU. For example: a hard disk might be attached using SATA3 or “SATA 6Gb/s,” representing a bus speed of 6Gb/s. Bus speeds on the CPU/motherboard (chipset layout) are more complicated and fine-tuned by the vendor. Components with fancy names such as North Bridge, South Bridge, and Front Side Bus (FSB) (http://en.wikipedia.org/wiki/Front-side_bus) are part of this architecture. Vendors typically offer systems with high-performance options where these speeds are optimized and enhanced compared with home use products.