# Background and Purpose

## Overview

Health registries greatly enhance health services research, especially when linked with other data sources such as administrative claims. Recently, concerns about patient privacy and data security have produced policies such as the Health Insurance Portability and Accountability Act (HIPAA) that reduce the availability of sensitive identifying information. In this context, the development of effective record linkage approaches for varying scenarios of data availability is critical. This report presents a conceptual framework and instructional information that scientifically describe the strengths and limitations of different approaches to record linkage of registries to other data sources. This chapter presents the context and motivation for the work detailed in subsequent chapters. Specifically, it describes the need for data linkages in general, and linkages of registries to health insurance claims specifically, in the context of comparative effectiveness research (CER) and the environments in which CER is conducted.

## Background

Randomized controlled trials (RCTs) remain the gold standard for assessing intervention efficacy; however, RCTs are not always feasible or sufficiently timely. Perhaps more importantly, RCT results often cannot be generalized due to a lack of inclusion of “real-world” combinations of interventions and heterogeneous patients.1–4 With recent advances in information technology, data, and statistical methods, there is tremendous promise in leveraging ever-growing repositories of secondary data to support comparative effectiveness and public health research.2,5–6 Observational studies of secondary data can help fill the knowledge gaps unaddressed by RCTs and extend the utility of current data investments by examining important research questions and health care programs. Because of this, the Institute of Medicine and others have strongly advocated for CER using secondary data from sources such as health registries, administrative claims, and electronic health records.7–10

Although these secondary data sources have many strengths, they also have important limitations. For example, because they are often collected for nonresearch purposes, secondary datasets do not have the benefit of randomization to control for confounders (factors associated with treatment and outcomes) that threaten to bias study findings.11–13 Moreover, individual datasets are often limited in scope, which in turn limits their utility in addressing important questions in a comprehensive manner. Some limitations can be overcome by linking data from multiple sources.7,14–16 Linking a registry with external data can facilitate case and control group identification, improve measurement of risk factors and outcomes, and allow passive followup of study participants.13,17–19 Linkages can also be used to refine and validate measures created using claims data or other registries20–22 or to adjust for unmeasured confounding by using supplemental data about a subset of observations.23 However, data linkage from multiple sources in support of CER and public health research continues to face several challenges.

Data linkage involves pairing observations from two or more files and identifying the pairs that belong to the same entity.24 A common form of linkage is to collect information on the same person from two datasets. However, linkage errors can arise from multiple points when data sources are inconsistent in capturing the same person, a person’s records do not link due to missing or inaccurate data in one or more files, or different people are erroneously linked for the same reasons.12 The causes of these errors are many, including poor data quality, data sources that use different systems for coding the linking variables in their records, inadequate capacity of linking software to handle large datasets, and complexity of data linking systems that have substantial learning curves. These factors can be compounded by recent policy changes that restrict access to key linking variables.

For public health and health care delivery settings, concerns regarding privacy, confidentiality, and safety have led to increasingly stringent policies and regulations governing the collection, use, and transfer of Personally Identifiable Information. Perhaps the most well-known patient privacy policy is HIPAA, which has been widely decried by health care programs and researchers as exemplifying the law of unintended consequences. Intended to protect patients from misuse of their personal information, the law has been associated with a substantially greater burden for both health care providers and researchers, and even indicted as contributory to patient deaths and research bias that may misinform and thus diminish the quality of future health care delivery.25–30 Indeed, a recent consensus report by the Institute of Medicine contends that HIPAA, passed with the intention of protecting patient privacy, does not protect privacy as well as it should, and agrees with assertions that HIPAA impedes important research.31 Policies such as HIPAA have severely limited access to unique identifiers (e.g., Social Security Numbers, names), traditional mainstays of quality data linkages involving person-level data,32–34 and many programs have even stopped collecting some identifying information.

In addition to concerns about availability of unique identifiers across datasets, there are several notable concerns regarding the datasets themselves. The validity threats due to nonrandomization include confounding by indication (treatment assignment influenced by risk for the outcome), selection bias (due to inability to define an appropriate control group), and misclassification of exposures or outcomes. Additionally, linkage errors can systematically bias effect estimates.11–13 Although researchers have continued to develop new methods for deterministic and probabilistic linkage, alternative methods have not been tested thoroughly and comprehensive guidelines are lacking.11,35–36

In light of these challenges, there is an urgent need to develop greater knowledge of how to perform reliable valid linkages to support the integration of disease registry and administrative data for health services research. Such linkages are important for leveraging the investment already made on the collection of the individual data sources and allowing their use for examining important CER and public health questions. Without such gains in knowledge and capacity, health care programs will miss substantial opportunities to use vastly expanding data resources to improve the public’s health, and many stakeholders will remain skeptical of clinical or policy decisions based on incomplete data.37–39

## Purpose

This report serves as a conceptual framework for data linkage in the context of CER. The report defines the requirements for high-quality record linkage of registries to other data sources and describes the strengths and limitations of different approaches. By explaining the spectrum of activities involved, it serves as an instructional guide for researchers designing new CER studies using patient registries linked with other secondary data sources. Through this report, we provide an overview of linkage from registries to administrative claims, including considerations for researchers, data managers, information technology managers, and other stakeholders who are likely to be involved in the process of data linkage. We also apply the data linkage framework to a real-world problem and discuss the results.

This report is informed by practical insight developed by researchers affiliated with the AHRQ (Agency for Healthcare Research and Quality) DEcIDE (Developing Evidence to Inform Decisions about Effectiveness) CER Consortium, who acquire, maintain, and link sensitive secondary data to support CER and outcomes research studies. Consistent with the goals of AHRQ and the DEcIDE Network, this report will enhance the ability of CER/patient-centered outcomes research to inform consumers, clinicians, policymakers, and other health care decisionmakers.

Record linkage in support of CER is more than simply joining two datasets. Rather, it is an extensive process that involves many steps and collaborations among multiple partners. Researchers hoping to link data sources should first be aware of the technical, legal, and data-management challenges and considerations. The remaining chapters in this report are designed to prepare researchers by providing them with the information necessary for high-quality data linkage.

Chapter 2 describes the components of a secure research environment. It is set in the context of building trust among data/research partners and includes technical and administrative guides to establishing a secure computing platform enabling sophisticated CER research. Additionally it discusses approaches to secure confidentiality, integrity, and availability of data in order to maintain compliance with State and Federal regulations.

Chapter 3 describes general considerations that must be addressed when planning to link data. The focus spans issues pertaining to requesting, receiving, and managing data from different sources; Data Use Agreements/Contracts; data ownership; and deciding whether data linkage is feasible and appropriate.

Chapter 4 guides the reader through an overview of data linkage methods in an effort to document a set of best practices for conducting linkages and recommendations for evaluating and reporting the validity and reliability of the linkage procedure selected. It begins with issues pertaining to the quality of the available linkage keys—specifically, completeness, overlapping information, and commonly observed idiosyncrasies. It focuses on the creation of a common data model via techniques for cleaning and standardizing the linkage keys before linkage. Next, an overview of data linkage methods is provided, including a detailed summary of deterministic and probabilistic linkage methods as well as techniques for evaluating the quality of the linkage. Finally, this chapter includes a set of appendixes that contain (1) lists and characteristics of several open-source and commercial software packages for data linkage, (2) sample SAS code for data preparation and linkage, and (3) recommended readings for those interested in learning more about alternative methods.

Chapter 5 presents an approach to linking registry data to administrative claims using the methods discussed in Chapter 4. Our approach involves four components: (1) employment of a gold standard, (2a) evaluation of deterministic approaches, (2b) evaluation of a deterministic approach using encryption, and (3) probabilistic approaches, each applied in varying scenarios of data availability to ascertain optimal approaches in given scenarios. In step 2b, a deterministic approach using encryption, we simulate a scenario of restrictions on identifier release to researchers. Given the exceptionally limited availability of practical empirical examples researchers can use to inform their own data linkages, this chapter articulates specific examples in depth, detailing the steps researchers may take and what they may expect to find given their unique scenarios of data availability and data quality.

Finally, Chapter 6 summarizes the report and provides specific recommendations for researchers who plan to undertake a data linkage project. We also provide information, including a checklist, for researchers to use in both the project planning phase and the project execution phase.