# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative effectiveness research
CPU: Central processing unit
DUA: Data Use Agreement
DEcIDE: Developing Evidence to Inform Decisions about Effectiveness
DOB: Date of birth
ePHI: Electronic Protected Health Information
EM: Expectation-maximization
FIPS: Federal Information Processing Standards
FISMA: Federal Information Security Management Act
GUID: Globally unique identifier
HIPAA: Health Insurance Portability and Accountability Act
IP: Internet Protocol
IRB: Institutional Review Board
IT: Information technology
LDS: Limited Dataset
NCCCR: North Carolina Central Cancer Registry
NIST: National Institute for Standards and Technology
NPV: Negative predictive value
PAYER: Claims data for beneficiaries in privately insured health plans in North Carolina
PHI: Protected Health Information
PII: Personally Identifiable Information
PIN: Personal Identification Number
PPIRL: Privacy Preserving Interactive Record Linkage
PPV: Positive predictive value
RAID: Redundant Array of Independent Disks
RAM: Random access memory
RCT: Randomized controlled trial
ROI: Return on investment
RPM: Revolutions per minute
SAN: Storage Area Network
SATA: Serial Advance Technology Attachment
Serial SCSI or SAS: Serial Attached Small Computer System Interface
SEER: Surveillance, Epidemiology and End Results
SFTP: Secure file transfer protocol
SHA-2: Secure Hash Algorithm version 2
SSD: Solid state disk
SSH: Secure command line
SSN: Social Security Number
SWOT: Strengths/weaknesses/opportunities/threats
URL: Universal Resource Locator
USB: Universal Serial Bus