# Results

## Background Work

The panel built upon a number of earlier efforts.

### Review of Initial Eight FRN Reports

Eight EPCs developed pilot FRN documents based on a previously completed AHRQ systematic review. These eight reports were:

- Prioritizing Research Needs in Gestational Diabetes Mellitus (Johns Hopkins University EPC)11
- Integration of Mental Health/Substance Abuse and Primary Care (RTI International—University of North Carolina at Chapel Hill EPC)12
- Reducing the Risk of Primary Breast Cancer (Oregon EPC)13
- Outcomes of Maternal Weight Gain (Vanderbilt EPC)8
- Treatments of Common Hip Fractures (Minnesota EPC)14
- Clinically Localized Prostate Cancer (Blue Cross and Blue Shield Association Technology Evaluation Center EPC)9
- Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease (Duke EPC)15
- Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Patients with Coronary Artery Disease (Tufts EPC)16

Of the initial eight Future Research Needs reports, half followed a broad, conceptual approach to identifying future needs8, 13, 14, 16 and the other half used a more focused approach. 9, 11, 12, 15 The type of approach dictated the type and level of detail provided in laying out future needs. Reports that followed a broad, conceptual approach, specified future research needs at the level of research areas or questions and presented lists of research questions that were sometimes organized as categories. These reports also tended to separate research questions from methodological considerations.

For example, the Vanderbilt EPC8 supplemented the gaps identified in the original CE review with additional gaps identified through a horizon scan of literature; they illustrated the content with an annotated causal framework. The Oregon EPC13 categorized the research gaps identified in the original CE review according to the most applicable element of the population(s), interventions, comparators, outcomes (PICO) framework. The Tufts EPC16 expanded the initial list of gaps based on the original CE review and feedback from a group of key informants with additions based on literature search and review of ongoing trials and refined in one-to-one interviews with key informants. They organized into the gaps four thematic areas: comparative effectiveness and safety of PCI (percutaneous coronary intervention) versus CABG (coronary artery bypass graft), role of testing to inform choice of revascularization procedure, methods to enhance patient population, and methods for assessing performance.

#### Tufts EPC Methods Report

The Tufts EPC methods report10 on defining an optimal framework for presenting research needs offered a number of recommendations that serve as a jumping off point for the workgroup’s deliberations. (We have added some annotations.)

1. Provide succinct yet adequate description of methods and results following guidelines for reporting of health care research (for example, there are reporting guidelines for qualitative research and modeling). Aim for a level of detail similar to that found in papers addressed to a general medical audience.
2. Be cognizant of the importance of the face validity of the process. Justify the selection of the stakeholders who participated in identifying or prioritizing research needs, and be clear on their degree of engagement.
3. Consider reporting the results of the future research needs assessment at two levels of detail. A suggestion would be to first present general areas that merit future research without specifying research designs or specific details on, for example, PICOTS elements. A second set of results could further elaborate on potential research designs, details on PICOTS elements, or other details as applicable.
4. Frame the more specific set of results as “examples” rather than as strict recommendations. (For example, it may be better to avoid specific numerical rankings and cluster recommendations into high and medium categories.)
5. Avoid explicit prioritization of research needs when there are no clear differences in the perceived strength of alternative recommendations, but acknowledge strong beliefs when they exist. Consider a tiered presentation of future research needs by grouping them in thematic entities (after the priorities have been established).
6. Clearly define how “feasibility” of future research was assessed. It may be instructive to perform power analyses for specific research designs for a range of assumptions and compare with the size of existing studies in the field.

#### RTI EPC Methods Project

The RTI EPC methods project17 on the advantages and disadvantages of different study designs for FRN discusses the terminology and presentation that could be used in FRN reports to describe study design considerations. The paper outlines common terminology for study designs and criteria for consideration of study designs. These criteria include resource use, size, and duration; availability of data and ability to recruit; ethical, legal and social issues; and advantages of study design for producing a valid result. Points taken from the paper for consideration by the workgroup include:

- Study design consideration comments may assist researchers and funders in determining whether to examine a given research question and guide the resources needed to address the research need. We anticipate that this information will provide a starting point for study planning and stimulate discussion. The FRN documents are intended to stimulate additional discussion among researchers and stakeholders, not truncate debate or planning. We do not intend that the future research considerations be prescriptive or exclude creative study designs or innovative use of existing data for CER.
- The criteria and terminology comments are generic, and will almost certainly need to be modified in a given FRN exercise, given the clinical and policy context of the condition under consideration.
- A degree of flexibility is necessary to apply these guidelines to considerations of study designs for future research needs. The advantages and disadvantages of a study design might change depending on the study question or the setting. The resources required for a study design depend on the intervention proposed. In addition, some study designs could be better suited for certain future research needs than other designs. Considerations should include an understanding of the context of the research including the nature of the factor being investigated and potential utility and quality of the data.

### Panel Statements, NIH Consensus Development Conferences

The NIH Consensus Development Program organizes conferences that generate evidence-based consensus statements addressing controversial issues important to health care providers, policymakers, patients, researchers, and the general public. The final key question of each NIH Consensus Development Conference relates to research needs, based on the evidence presented in these conferences. The workgroup scanned the relevant portions of these panel statements.

The scope of questions asked was variable and depended on the state of the science. Examples include:

- Preventing Alzheimer’s Disease and Cognitive Decline. If recommendations for interventions cannot be made currently, what studies need to be done to provide the quality and strength of evidence necessary to make such recommendations to individuals?19
- Vaginal Birth After Cesarean: New Insights. What are the critical gaps in the evidence for decisionmaking, and what are the priority investigations needed to address these gaps?20
- Inhaled Nitric Oxide Therapy for Premature Infants. What are the future research directions needed to better understand the risks, benefits, and alternatives to nitric oxide therapy for premature infants who receive respiratory support?18
- Lactose Intolerance and Health. What are the future research needs for understanding and managing lactose intolerance?21
- Enhancing Use and Quality of Colorectal Cancer Screening. What research is needed to make the most progress and have the greatest public health impact in promoting the appropriate use of colorectal cancer screening?22

The scope, detail, and organization of recommended research directions varied across the panel statements. Methods of presentation included a numerical list, thematic approach, and narrative. Types of identified research needs were both methodological and topical and also included recommendations for infrastructure development as well as basic research in the field. Methods type research needs included use or development of consistent measures, reporting, and study design methodology. Often the description of the research need included a rationale that highlighted the importance of filling the need in terms of a patient outcome. Research design considerations were also frequently included, though the level of detail was also variable. While almost no one advocated a particular research design, many made mention of considerations related to power, subgroups, appropriate comparators, intervention details (timing, dosing, etc.), relevant outcomes, and contextual factors. When research designs were mentioned, they were frequently presented as an example among other potential approaches. For research designs presented as a recommendation, the panel included a rationale and did not include specifics in terms of sample size or other details.