# References

1 Committee on Comparative Effectiveness Research Prioritization and Institute of Medicine. (2009). Initial National Priorities for Comparative Effectiveness Research.
2 Whitlock EP, Lopez SA, Chang S, et al. (2010). AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol.
3 Eden J, Levit L, Berg A, et al. (2011). Finding What Works in Health Care: Standards for Systematic Reviews.
4 Trikalinos T, Dahabreh I, Lee J, et al. (2011). Methods Research on Future Research Needs: Defining an Optimal Format for Presenting Research Needs. Methods Future Research Needs Report No. 3 Tufts Evidence-based Practice Center.
5 Robinson KA, Saldanha IJ, McKoy NA. (2011). Frameworks for determining research gaps during systematic reviews.
6 Methods Research on Future Resarch Needs: Framework for Considering Study Designs for Future Research Needs (FRN). Draft prepared for Agency for Healthcare Research and Quality.
7 O'Haire C, McPheeters M, Nakamoto EK, et al. (2011). Methods for Engaging Stakeholders to Identify and Prioritize Future Research Needs, Methods Future Research Needs. Report No. 4.
8 McKoy JN, Hartman KE, Jerome RN, et al. (2010). Future Research Needs for Outcomes of Weight Gain in Pregnancy, Future Research Needs Paper No. 6.
9 Mauger Rothenberg B, Marbella A, Belinson SE, et al. (2010). Future Research Needs for Comparative Effectiveness of Treatments for Localized Prostate Cancer, Future Research Needs Paper No. 4.
10 Trikalinos TA, Dahabreh IJ, Lee J, et al. (2011). Methods Research on Future Research Needs: Defining an Optimal Format for Presenting Research Needs, Methods Future Research Needs Report No. 3.
11 Bennett WL, Nicholson WK, Saldanha IJ, et al. (2010). Future Research Needs for the Management of Gestational Diabetes, Future Research Needs Paper No. 7.
12 Carey TS, Crotty KA, Morrissey JP, et al. (2010). Future Research Needs for the Integration of Mental Health/Substance Abuse and Primary Care, Future Research Needs Paper No 3.
13 Guise J-M, Nakamoto EK, LaBrant L, et al. (2010). Future Research Needs to Reduce the Risk of Primary Breast Cancer in Women, Future Research Needs Paper No. 5.
14 Butler M, Forte ML, Kane RL, et al. (2010). Future Research Needs for the Treatment of Common Hip Fractures, Future Research Needs Paper No. 2.
15 Sanders GD, Powers B, Crowley M, et al. (2010). Future Research Needs for Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease, Future Research Needs Paper No. 8.
16 Trikalinos TA, Dahabreh IJ, Wong J, et al. (2010). Future Research Needs for the Comparison of Percutaneous Coronary Interventions with Bypass Graft Surgery in Nonacute Coronary Artery Disease, Future Research Needs Paper No. 1.
17 RTI EPC Methods Project (Draft on EHC site).
18 Cole FS, Alleyne C, Barks JD, et al. NIH Consensus Development Panel Statement—Inhaled Nitric Oxide.
19 Daviglus ML, Bell CC, Berrettini W, et al. (2010). National Institutes of Health State-of-the-Science Conference Statement: Preventing Alzheimer's Disease and Cognitive Decline. NIH Consens State Sci Statements.
20 Cunningham FG, Bangdiwala S, Brown SS, et al. (2010). National Institutes of Health Consensus Development Conference Statement: vaginal birth after cesarean: new insights. Obstet Gynecol.
21 Suchy FJ, Brannon PM, Carpenter TO, et al. (2010). NIH Consensus Development Conference Statement: Lactose Intolerance and Health. NIH Consens State Sci Statements.
22 Steinwachs D, Allen JD, Barlow WE, et al. (2010). NIH Consensus Development Panel Statement: Colorectal Cancer Screening. Consens State Sci Statements.
23 Robinson KA, Saldanha IJ, McKoy NA. (2011). Development of a framework to identify research gaps from systematic reviews. J Clin Epidemiol.
24 Gaynes B, Christian R, Saavedra L, et al. (2012). Future Research Needs for Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-Risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment, Future Research Needs Paper No. 9.
25 Powers BJ, Crowley MJ, McCrory DC, et al. (2012). Future Research Needs for Comparing Angiotensin-Converting Enzyme Inhibitors (ACEIs), Angiotensin II Receptor Antagonists (ARBs), and Direct Renin Inhibitors (DRIs) in the Treatment of Hypertension.