# Recommendations

## General Recommendations

The FRN, whether methodological or topic-specific in nature, should be presented as a top tier rather than a numerical list. The level of detail of the FRN description will depend on the state of the science, and EPCs should use their judgment based on their understanding of the topic and field.

Basic principles include:

- Rationale for prioritization if possible.
- Research design considerations for the FRN should be offered as suggestions only to avoid appearing overly prescriptive.

The workgroup recommended separating the presentation of two elements of potential future research: methods issues and specific topics. Methods issues tend to transcend specific topics. They should be ranked separately.

## FRN Methods Framework

The workgroup identified a number of potential methodological issues that an FRN might address. Table 1 identifies elements that should be considered when addressing methods issues.

Table 1 Potential issues for methodological future research needs

Issues | Potential Details To Be Addressed for Each Issue
Designs | - What research designs are most appropriate for specific questions? What are the barriers to conducting the optimal kind?; - How much information is needed regarding the study design and study elements such as intervention and patient characteristics?; - Where possible, future research needs reports should allude to elements needed to improve the strength of evidence from the initial Comparative Effectiveness Review.
Actions that facilitate aggregations of results | - For each clinical area, to facilitate comparisons and aggregation across studies, we need common measures and definitions for condition(s) under investigation, elements of interventions, major outcomes, and harms.; - Focus on harms as well as benefits when appropriate.
Inclusion of multiple perspectives | - Incorporate various disciplinary perspectives. The focus of different disciplines in terms of the emphasis on patients or treatments may vary.
Statistical analysis | - Specify interactions to identify differences in effects across subgroups.; - Specify when certain diagnostic categories should be in or out of a study.

For each relevant issue, the FRN should address elements and level of detail and explain how this fills the evidence gap.

An example of a methodological gap identified in an FRN relates to treatments for localized prostate cancer. Because of the lengthy course of this disease, some randomized controlled trials have been published with high crossover rates in which patients have taken the initiative to receive the treatment to which they were not randomized. This is understandable from the patient’s perspective but may greatly reduce the ability to draw conclusions from the trial. Research was therefore recommended on “Exploring methods to increase patient adherence with randomization scheme.” This might include surveys to help understand participants’ decision-making; and measuring the effectiveness of approaches intended to reduce unplanned crossing over to another arm. Research was also recommended to increase the use of statistical modeling and other advanced methods in studies on localized prostate cancer.

## FRN Topics Framework

The steps in this process may be summarized as follows:

- Include reason why the FRN is prioritized as high. May include criteria used (burden, feasibility, impact).
- Organize by PICOTS.
- Use analytic framework if possible, and adapt if needed. Consider including relevant issues such as subgroups, settings, and other contextual issues.
- Level of detail of FRN description depends on the state of the science.
- Research design considerations for the FRN should be offered as suggestions only to avoid appearing overly prescriptive.

The presentation of specific research topics should include a rationale as well as an organized presentation of each topic. Provide text description of why the prioritized questions are particularly urgent to be answered. Criteria for choosing topics should reflect why answers to the prioritized questions are particularly urgent. Proposed criteria include:

- Societal burden
  ○ Costs
  ○ Harms
- Feasibility of research
- Likelihood results will affect practice/policy (for patients as well as others)

The PICOTS formulation should be used to present each recommended topical research question in a separate table for each question. An example of using the PICOTS framework to structure future research recommendations comes from the report Future Research Needs for Attention Deficit Hyperactivity Disorder: Effectiveness of Treatment in At-Risk Preschoolers; Long-Term Effectiveness in All Ages; and Variability in Prevalence, Diagnosis, and Treatment24 (see Table 2).

Table 2 Excerpt from “Future Research Needs for Attention Deficit Hyperactivity Disorder”

P | I | C | O | T | S
Age <6 years Diagnosed with ADHD or at risk for ADHD or diagnosed with Disruptive Behavior Disorder (including Oppositional defiant disorder (ODD) and Conduct disorder (CD) | Initial treatment with psychosocial and/or pharmacologic treatments or Addition of a psychosocial and/or pharmacological treatment to an existing treatment after treatment failure | Initial treatment with psychosocial and/or pharmacologic treatments or Continuation of existing treatment without addition of psychosocial and/or pharmacologic treatment or switch to different treatment | Outcomes for children and parents^*^ | Months/Years | Private clinic, community clinic, school, home

* Outcomes for children and parents include change in ADHD symptoms, social functioning, emotional regulation, executive functioning, treatment adherence, behavior problems, global functioning, academics, and parent competence, and harms, such as behavioral side effects, sleep difficulties, appetite/metabolic concerns, and cardiovascular changes.

Graphical frameworks are often used in grants to clearly communicate ideas, linkages, and assumptions to demonstrate that the research proposed is well-integrated, well-reasoned, and appropriately designed to advance a field of research. Analytic frameworks have been used to structure comparative and systematic reviews but were not intended to guide discussions of future research, although work is underway to adapt them to FRNs when feasible. However, analytic frameworks depict the population, interventions, comparators, outcomes, timing, and settings (PICOTS) which are often key elements in research study designs. Future research chapters of CE reviews often mention the need for more research on special populations (including racial, ethnic, and genetic variations), settings (e.g., community or geographic), contextual features such as patient-provider communication and decisionmaking, and influencing factors as important topics for future research. Thus an analytic framework may be an effective method to display these considerations and their linkages to interventions and their outcomes. The report should employ a conceptual model or logic diagram when appropriate; not all FRN topics may be suitable for this. For example, research questions may address prevalence in subgroups. The model should be based on current thinking and not limited to what was in the parent report.16

An example of the use of a framework adapted for an FRN document comes from Future Research Needs To Reduce the Risk of Primary Breast Cancer in Women,13 which used an analytic framework that incorporated the priority research area, research needs, and potential study designs (Figure 2). This flowchart depicts an enhanced conceptual framework to illustrate priorities for future research to reduce the risk of primary breast cancer in women. The chart emphasizes high priority research domains and depicts “influencing factors” important to stakeholders and integral to patient-centered care: health system/organization, social, educational, economic, and environmental factors. A series of research questions are applied to these high priority research domains, with the overall goal of understanding which interventions are most effective to reduce risk of breast cancer for which patients under what circumstances.

Figure 2 Analytic framework from “Future Research Needs to Reduce the Risk of Primary Breast Cancer in Women”

Figure 2 illustrates how the PICOTS approach can be applied to prevention of primary breast cancer. The population is defined and classified to eliminate borderline candidates. The interventions include medication, diet, exercise, behavioral interventions and others. Other influences are considered, such as the health system, social factors (including family), socio-economics, and environmental or setting factors. Intermediate outcomes include breast cancer incidence. Health outcomes include mortality, morbidity and quality of life. Harms can occur as a result of screening or interventions.

As part of the process of the most salient FRNs, EPCs engage a wide variety of stakeholders who may identify a broad list of new potential research areas. It should be noted that these new areas of research will likely not be based on an assessment of the evidence (or lack of evidence) because they fall outside of the scope of the parent evidence report.

The level of detail in presenting recommendations will vary with the topic. Research in some areas may have sufficiently developed to the point where the gap can be precisely defined (e.g., testing a specific intervention or comparing two specific interventions). In other areas, the suggestions may be couched more broadly about types of questions or interventions. Likewise, the specificity of research design considerations may vary with the circumstance. In some cases, but not all, the appropriate design will be evident. There may be design tradeoffs or specific issues to consider. Include any research design considerations or comments if relevant. For example, it would be inappropriate to recommend that you must do an RCT with X number of people, but it would be fitting to suggest (as opposed to recommend) that future research should be appropriately powered to study X subpopulation. EPCs will need to decide when the research design issues are sufficiently clear that they can be urged.

## Considerations for Research Designs

In looking at the entirety of the literature, evidence reviews may uncover important insights regarding study designs that would help advance the science. For example, in a review of the treatment of hip fracture, it became clear that the studies conducted by epidemiologists emphasized patient characteristics, and those by orthopedic surgeons emphasized treatments, but neither captured the whole terrain. FRN authors may want to consider including appropriate research considerations. FRN documents aim to delineate where there is an absence of studies and also to describe limitations of existing studies to the extent that researchers could improve upon those limitations. It can be a delicate balance to provide sufficient detail to be helpful to researchers while not being so prescriptive that research creativity and discovery are stifled. As opposed to identifying gaps in research, there may be important design issues to consider. When there are fatal flaws in prior study designs, future research needs documents should describe the flaws and potential design remedies in sufficient detail that interested researchers could improve their study designs accordingly. The amount of detail that should be shared in FRN documents will depend on the topic and specifics of the report. In fields with relatively little evidence, a broad translational table presenting the spectrum of study designs that would be acceptable to inform certain research gaps may be most useful. In other areas, where there is a substantial body of literature, a deeper description of important flaws in existing studies that are hampering the strength of certainty in results is appropriate.

A common issue that future research documents can inform across topics addresses the role for observational studies and comments about the context in which observational studies may be suitable or even preferable for certain needs. For example, while there may be randomized controlled trials of screening, the question about the adverse consequences of screening (or the long-term effects) may be best answered through an observational study. While each report will differ on the extent to which details about study designs can be discussed, it is the general intent to describe important flaws and provide insights into possible solutions while promoting the creativity that advances discovery.

An example of how study design can be addressed while leaving reasonable latitude can be found in the future study recommendations in Future Research Needs for Angiotensin-Converting Enzyme Inhibitors (ACEIs), Angiotensin II Receptor Antagonists (ARBs), or Direct Renin Inhibitors (DRI) for Treating Hypertension25 (Table 3).

Table 3 Excerpt from “Future Research Needs for Angiotensin-Converting Enzyme Inhibitors (ACEIs), Angiotensin II Receptor Antagonists (ARBs), or Direct Renin Inhibitors (DRI) for Treating Hypertension”

Research area | RCT? | Meta-analysis or individual patient data analysis across RCTs? | Meta-analysis of observational studies? | New observational study? | Analysis of existing data? | Model?
What is the comparative effectiveness of these medications on cardiovascular and cerebrovascular events measured over several years? | Maybe: Large number of studies recently completed or ongoing in patients with other comorbidities may make new RCTs unnecessary | Maybe: If recent data is not included in original CER or if it is methodologically valid to combine studies of medication impact across different conditions (such as hypertension, ischemic heart disease, chronic kidney disease) | Maybe: If sufficient number of studies available; adjustment for confounding could be an issue | Maybe: Most direct way to address long-term outcomes; however, resource requirements for longer-term studies are potential limitations | Yes: Most efficient method for evaluating long-term outcomes given the large number of existing studies; appropriate coding for covariates an issue | Maybe: Potential role for helping determine clinically important differences
What is the impact of comorbidities (such as ischemic heart disease, CHF, diabetes, peripheral arterial disease, chronic kidney disease) on ACEI/ARB/DRI effectiveness or harms in patients with hypertension? | Maybe: May be feasible for common comorbidities; existing or ongoing studies might be sufficient for some | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis; would require cooperation from the multiple sponsors of RCTs in this area | Yes: If individual patient data or separate subgroup data not reported in current trials could be obtained and pooled for analysis; would require cooperation from the multiple sponsors; if available, could address less common comorbidities, long-term safety/effectiveness | Maybe: Most direct way to address less common comorbidities; allows for adjustment for confounding; sample size and resources needed for longer follow-up are potential limitations | Yes: Most efficient method for evaluating less common comorbidities over longer time frames; appropriate coding of covariates a potential limitation | No: Except for potential role in defining clinically or economically meaningful differences

For specific details related to considerations of research designs in FRN documents, please refer to the RTI EPC methods paper on Advantages and Disadvantages of Different Study Designs for Future Research Needs.17