# Introduction

This methods paper was commissioned by the Agency for Healthcare Research and Quality (AHRQ) as one of a series of papers addressing methods issues in the relatively new area of explicit discussion of future research needs (FRN) as part of comparative effectiveness research (CER). This paper is intended to reflect current and recommended practices for the AHRQ Evidence-based Practice Centers (EPC), but these methods will certainly be refined in the coming years through both the EPC program and related initiatives as envisioned by the Affordable Care Act. Other papers in this methods series on future research needs in comparative effectiveness research may be found on AHRQ’s effective health care (EHC) Web site: www.effectivehealthcare.ahrq.gov/futureresearchneedsmethods.cfm.

## Comparative Effectiveness Research

CER is the “generation and synthesis of evidence that compares the benefits and harms of alternative methods to prevent, diagnose, treat, and monitor a clinical condition or to improve delivery of care. The purpose of CER is to assist consumers, clinicians, purchasers, and policymakers to make informed decisions that will improve care both at the individual and the population levels.”1 CER comprises a broad range of activities and types of study, encompassing systematic reviews, secondary data analyses, randomized controlled trials, prospective observational studies, health systems research, and dissemination of results to the public, providers, policymakers, and other key stakeholders. Key components of CER include comparisons between active treatments, policies, or diagnostic strategies with evidence from research conducted in settings similar to those in which most patients with a given condition are treated. The explicit nature of CER is demonstrated by the descriptions of proposed study questions through the PICOTS formalism, in which each Key Question is described using six dimensions: Population; Intervention; Comparator treatment or test; Outcomes assessed; Timeframe; Study setting.2

## Future Research Needs

Systematic reviews of focused clinical and policy questions reach conclusions whenever feasible and describe the strength of evidence supporting those conclusions. However, many reviews find only low or moderate strength of evidence to address a given Key Question. Problems are often identified with the amount or quality of the literature examined, leading to an inability to address all of the components of the key study questions to sufficiently address the clinical and policy needs that led to the Key Questions. Gaps in the evidence remain. A common criticism of systematic reviews is that, while they generally contain a section describing the limitations of the research just reviewed, these limitations sections often are very general (e.g., “larger trials are needed”) and provide relatively little guidance to funders or the research community regarding the next study or series of studies needed to advance a given field.3 Yet a key, and to date, underutilized role of the systematic review process is to stimulate new research to address identified gaps in the literature.

With these FRN papers and accompanying methods papers, the AHRQ EPC Program distinguishes between the evidence gaps that are identified from within a systematic review and those that are prioritized and clearly defined as research needs by stakeholders based on their potential impact on practice or care. A more explicit and prioritized listing of research needs, with guidance regarding how to address those needs, could allow the impact of systematic reviews to be more fully realized and increase the pace of research to provide meaningful answers. The audience for future research needs reports includes the research community, funders, policymakers, and advocacy groups. Reducing the time between synthesis of evidence, identification of future research needs, and initiation of studies to address those needs is urgently needed in the current health care environment.

### The Future Research Needs Process

In the AHRQ EHC program, FRN documents are derived from systematic reviews of CER questions. The FRN document follows online publication of the systematic review and serves as a standalone document. Figure 1 shows the flow of an FRN project.

Figure 1 Flowchart of future research needs process

* May include identification of additional evidence gaps.

† Reduction through topic consolidation, preliminary prioritization, and consideration of ongoing research (duplication criteria).

‡ Evidence gaps that address specific methods issues would not use PICOTS framework

¥ May require iterative steps

Figure 1 describes the flow of steps in developing future needs report. There include: ∙ Beginning with the original evidence gaps in the systematic review ∙ Orienting stakeholders to the goals and criteria for a future needs report ∙ Working with stakeholders to elaborate the potential items ∙ Creating future research questions ∙ Ranking the pool of questions ∙ Adding study design and feasibility considerations ∙ Publishing the FRN report

Each FRN report begins with identifying a list of evidence gaps from the systematic review (in draft or final form), which may be augmented with input from a multidisciplinary panel of stakeholders familiar with both the research methods and the clinical and policy content of the systematic review. The EPC then works with the stakeholder group to elaborate and consolidate the evidence gaps, taking into consideration any ongoing or planned research that may already be addressing gaps. Potential research questions are then elaborated following the PICOTS framework with the exception of methodological questions, which may be organized differently.4 Once the questions have been formalized, they are given a final ranking by the stakeholders according to potential value criteria. The final list of 4–12 high priority Future Research Needs with specific questions, including PICOTS definition (as appropriate) and potential study designs, is published in a final document intended for use by researchers and funders of research.

### Scope of This Paper

This paper is one of a series of papers that provide recommendations and best practices on the steps in identifying and prioritizing Future Research Needs. (This particular paper addresses issues around presenting the findings from an FRN analysis, which are covered in steps 4, 6, and 7. This paper does not address other related issues around determining research gaps, orienting stakeholders to CER questions, FRN process and prioritization criteria, elaboration of evidence gaps, and ranking research needs, within steps 1, 2, 3, and 5, which are covered in related papers.5–7) Other papers that address other steps in the FRN process will be posted as they are completed at www.effectivehealthcare.ahrq.gov/futureresearchneedsmethods.cfm.

## Background and Rationale

The goal of the FRN documents is to encourage further research based on the shortcomings identified in the comparative effectiveness (CE) reviews, by extending the discussion raised in those reports. We walk a fine line between stimulating action and appearing overly prescriptive. The question of the “desirable” level of detail in laying out future research needs is related to larger questions of:

- Who is the primary audience for the reports (funding agencies, researchers)?
- Is the prioritization activity a technical exercise in which solutions (highly specified research studies to address research needs) are found?
  or
- Are stakeholders engaged in a prioritization activity that leads to insights and broad understanding of research needs?

These questions may also be related to the extent of the evidence base in the underlying field of research. It is possible that fields with a large evidence base are more amenable to focused prioritization efforts that yield highly specified research questions.

Stakeholder perspective offers some clues about which approach (technical or broader insights) may be the most appropriate. In some cases, stakeholders may move the identification to a broader plane than was originally anticipated. For example, the future research needs report on weight gain in pregnancy offered the following narrative: “Stakeholders were reluctant to dictate a specific form of study design because they felt that many of the research areas were at a nascent stage that might benefit from a multiplicity of approaches. In addition, while the group was inspired to map the identified research priorities to study approaches, they were reluctant to specify a single, correct next step. They expressed confidence in the collective energy and creativity of the scientific community, suggesting that agencies and organizations seeking to advance research in this area solicit and amply fund investigator-initiated research rather than prespecifying study designs to answer high priority questions. Likewise there was confidence that robust expertise and appropriate study populations are available to realize answers to the prioritized questions quickly in order to bring practical tools and new knowledge to advancing the care of women and their children.”8

Stakeholder reactions varied for other topics. For example, members of the stakeholder panel on treatment for localized prostate cancer9 took into account two large, lengthy randomized controlled trials that were then underway and sought to identify potential studies and research designs that could enrich the evidence base while awaiting the results of those trials. They also shifted the emphasis from specific treatments to determining which patients should be treated and when, because of their concern about substantial overtreatment in this patient population.

In addition to the pilot work in FRN documents, recognizing that this was a new area of work, these eight centers were also engaged in methodological development to provide an underpinning for eventual programmatic guidance. One of these projects was devoted to defining an optimal format for presenting research needs.10

As a result of these early experiences in piloting approaches to FRN development and prioritization, and exploration of methods, AHRQ has identified the need for program guidance on a structured and consistent method for presenting FRNs. Initial efforts have been made to create guidance, but initial experience has suggested that further refinements are indicated.

### Aims

This project explores how recommendations for FRNs beyond the work done in CE reviews can be best organized and presented across a variety of topics. It delineates the elements and presentation that are most helpful in a standalone future research needs document.

In the context of the FRN document, this relates specifically to the way the prioritized list of research needs (the “future research needs”) are presented. Early experience suggests two categories of research gaps, one related to the topic area and another related to methodological issues. This report will inform presentation elements and the level of detail that are appropriate for each.