# Peer Reviewers

Mary Butler, Ph.D.

Minnesota Evidence-based Practice Center

Karen Robinson, Ph.D., M.Sc.

Johns Hopkins University Evidence-based Practice Center

Melissa McPheeters, Ph.D., M.P.H.

Vanderbilt University Evidence-based Practice Center