# Conclusion

The workgroup reviewed relevant documents from sources within the EPC program and external sources. The recommendations are based on the information gleaned from previous experience of the workgroup members, recommendations from methods work, and from exemplars of this work from multiple sources. We expect that further development in this area will continue as EPCs gain more experience in FRN work and the program receives feedback from stakeholders.

The methodology committee of the newly formed Patient Centered Outcomes Research Institute has been tasked with creating a translation table, which is intended to “provide guidance and act as a reference…to determine research methods that are most likely to address each specific research question (U.S. Public Law 111-148, section 301). This additional guidance will also contribute to the development of FRN work within the EPC program.