# Acknowledgments

The authors gratefully acknowledge Tim Carey for his comments on an earlier version of this report.