# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CABG: coronary artery bypass graft
CE: comparative effectiveness
CER: comparative effectiveness research
EPC: Evidence-based Practice Center
FRN: future research needs
PCI: percutaneous coronary intervention
PICO: Population(s), Interventions, Comparators, Outcomes
PICOTS: Population(s), Interventions, Comparators, Outcomes, Timing, Settings