# Role of Study Design Considerations Within Future Research Needs

The EPCs add a short discussion of study design considerations specific to each of the highest-priority research needs after stakeholders prioritize the needs (see Step 6 in Figure 1). The purpose of this discussion in the FRN document is to leverage the knowledge gained in the systematic review process and assist funders, researchers, and stakeholders in further describing how a subsequent research project, potentially initiated by funders, advocates, or policymakers and conducted by researchers, might approach meeting an FRN. Adding the study design considerations to the FRN document takes advantage of the time and expertise dedicated to future research by the EPC team and stakeholders in developing the needs. Because more than one study design may be appropriate to address a given research need, these are simply considerations and are not intended to be prescriptive. The discussion of study design in the AHRQ FRN documents should be only a first step in developing a research project, giving funders, policymakers, and researchers some initial ideas that will hopefully stimulate discussion and additional efforts.

To maintain consistency across the future research papers and to communicate clearly with stakeholders regarding FRN projects, terms must be clearly defined and a set of basic dimensions must be considered across all reports, although the conclusions will vary according to the specific topic. Therefore, this paper proposes terminology and methods of presentation of FRN study design consideration materials to provide consistency and a common language for future reports. This document presents the early stage of development for these methods; we expect that they will be refined in the months and years to come.