# References

1 Institute of Medicine. (2009). Initial national priorities for comparative effectiveness research.
2 Whitlock EP, Lopez SA, Chang S, et al. (2010). AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol.
3 Eden J, Levit L, Berg A, et al. (2011). Finding what works in health care: standards for systematic reviews.
4 Trikalinos T, Dahabreh I, Lee J, et al. (2011). Methods research on future research needs: defining an optimal format for presenting research needs, Methods Future Research Needs Report No. 3.
5 Robinson KA, Saldanha IJ, Mckoy NA. (2011). Frameworks for determining research gaps during systematic reviews, Methods Future Research Needs Report No. 2.
6 Owens DK, Lohr KN, Atkins D, et al. (2010). AHRQ Series Paper 5: Grading the strength of a body of evidence when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol.
7 Hartling L, Bond K, Harvey K, et al. (2010). Developing and Testing a Tool for the Classification of Study Designs in Systematic Reviews of Interventions and Exposures.
8 Butler M, Forte ML, Kane RL, et al. (2010). Future research needs for the treatment of common hip fractures, Future Research Needs Paper No. 2.
9 Viswanathan M, Visco AG, Hartmann K, et al. (2006). Cesarean Delivery on Maternal Request, Evidence Report/Technology Assessment No. 133.
10 Mauger Rothenberg B, Marbella A, Belinson SE, et al. (2010). Future Research Needs for Comparative Effectiveness of Treatments for Localized Prostate Cancer, Future Research Needs Paper No. 4.
11 Trikalinos TA, Dahabreh IJ, Wong J, et al. (2010). Future Research Needs for the Comparison of Percutaneous Coronary Interventions with Bypass Graft Surgery in Nonacute Coronary Artery Disease: Identification of Future Research Needs from Comparative Effectiveness Review No. 9.
12 Spaulding C, Daemen J, Boersma E, et al. (2007). A pooled analysis of data comparing sirolimus-eluting stents with bare-metal stents. N Engl J Med.
13 Berger JS, Elliott L, Gallup D, et al. (2009). Sex differences in mortality following acute coronary syndromes. JAMA.