# Issues in the Application of the Framework to Future Research Needs Projects

A discussion of study design considerations may assist researchers and funders in determining whether to examine a given research question and guide the resources needed to address the research need. We anticipate that this information will provide a starting point for study planning and stimulate discussion. We do not intend that the future research considerations be prescriptive or exclude creative study designs or innovative use of existing data for CER. Some promising research options may not be considered by the EPC team and stakeholders. The FRN documents are intended to stimulate additional discussion among researchers and stakeholders, not truncate debate or planning.

## Composition of the FRN Team

Addressing study designs to collect new information is a qualitatively different activity from systematic review. Systematic review requires knowledge of a range of study designs and analytic methods, as well as deep knowledge of the strengths and weaknesses of each. Part of a systematic review is acquiring knowledge of specifics of the clinical condition and its treatments. Such knowledge is intrinsic to study quality and overall strength of evidence assessments. However, the members of the FRN team may not necessarily have personal experience with conducting the study designs and especially not conducting the study design in the subject area of the report. As generalists, EPC teams bring epidemiologic methods expertise and broad perspective to the work, but experience in specific study conduct issues such as subject recruitment, prevention of subject dropout, management of cointerventions, and cross-over between study groups can be helpful. EPC core staff may not have expertise in all these areas. Recruiting an FRN team member with expertise in these study conduct areas can provide a practical balance to the general epidemiological methods expertise. Also helpful will be maintaining the focus on the key questions addressed in the original systematic review and the gaps identified in that review through the GRADE ratings and other methods. The members of the stakeholder panel can provide additional perspectives but should not be considered a substitute for such expertise on the study team. Stakeholders have subject expertise and are often experienced researchers in the area but cannot be expected to devote the time to provide detailed methods advice.

## Timing of Study Design Application

Study design considerations will be developed by the EPC team after the evidence gaps have been translated into FRNs and after priorities are assigned by the FRN stakeholder group during conference calls and prioritization exercises. Stakeholders assist the EPC team in identifying potentially many evidence gaps and then prioritize the gaps into high and low priority, in recognition that not all evidence gaps can be resolved in a short period of time. Design considerations will be assigned only for the final high-priority FRNs. As the FRN projects are currently conducted, the stakeholders do not have an opportunity to review and comment on the proposed study designs until the report is posted for public comment. During the public comment period, stakeholders and other members of the public can simultaneously critique the draft study design considerations.

## Weighing Different Considerations in Study Designs

Report authors will need to use judgment to arrive at FRN recommendations for study designs. We recommend that the report authors consider the factors of resource use, ethical factors, data availability and recruitment feasibility, and validity when recommending one or several designs to funders, researchers, and policymakers. The emphasis on each factor will vary depending on the health care condition or problem being examined and the specific issues raised by each FRN. We do not feel that a specific quantitative weighing or scale is appropriate to assess the overall desirability of a given study design. Such a process would be ad-hoc and justifiably subject to criticism. In addition, a substantive ethical problem would, of course, trump any validity or resource use advantage. The most prominent example of assessing study designs is the peer review process used by the National Institutes of Health and AHRQ, which assigns individualized scores to components of a fully elaborated research proposal (e.g., significance, impact, approach, investigators, environment)—the summative score is not a combination of the individual scores, but rather a standalone 1 through 9 numeric score. For FRN reports, we recommend that the authors list and assess one to three study designs for each of the final high-priority FRNs, with limited textual description—just enough that a reader can understand the rationale for the choices. The FRN team will need to strike a balance between being overly prescriptive and provocative regarding study designs and being too general and bland to be helpful to stakeholders not involved with the process.

## Sample Size Calculations

One descriptor that can guide researchers and funders in planning a future research project is the anticipated number of subjects needed for the study design within a given condition. Sample size in any study depends on multiple factors: the study outcome and its frequency, the variance of the outcome when it is a scale, the anticipated dropout rate, and the difference in the study outcome between the intervention and comparator groups that is needed to be of clinical or policy importance. As part of study planning investigators do, of course, discuss sample size issues in some detail, so the use of sample size calculations in an FRN document should be considered only a first approximation. Such discussion can be useful, however, in illustrating some of the challenges inherent to CER. By definition, CER involves comparing two active treatments, tests, or policies as opposed to a no treatment or a placebo comparison group. The effect size identified between two active interventions is generally smaller than the effect size between either active intervention under consideration and a placebo or no treatment. A larger sample size will, therefore, be needed in the CER study to detect this smaller difference. Sample size calculations in FRN documents should be regarded as illustrative, not definitive, and may not be needed for all FRNs. When sample size estimates are provided, the basis for the sample size calculations (e.g., event rates) should be referenced. An example of sample size calculations to inform feasibility of specific designs is provided at the end of this manuscript (Example 4).

## Format

Either a narrative (several sentences up to one to two paragraphs) or a tabular format could be used in presenting study design considerations to readers. In the examples that follow, we present both formats. A table is most appropriate for straightforward designs, while a narrative approach is most appropriate for methods studies or for situations in which a study design choice might depend on a number of factors. For example, a community-based RCT might be an optimal study design in some circumstances, but success in such a trial might be conditional on development of brief, acceptable, and valid outcomes instruments. Such considerations would be more clearly presented in text than a table.

## Discussion of Study Designs Not Included in the Systematic Review

Some study designs recommended to address FRNs may include designs that are not RCTs or controlled studies or designs that rely on retrospectively collected data. Such study designs may be useful to address specific gaps regarding generalizability of findings from RCTs and methods issues or to identify possible harms in large populations when the study samples in RCTs may be too small or not sufficiently generalizable as part of the evaluation of a drug or technology. Although projects funded under the American Recovery and Reinvestment Act of 2009 (ARRA-funded projects) focus on CER with active treatment comparators, a CER review may include findings that treatment efficacy compared with placebo has not been established or has not been established for some key subpopulations. Additional RCT efficacy trials would therefore be in order. These designs are generally within scope of the key questions of the original systematic review.

For example, several FRN projects to date have found that there is a gap in valid measurement instruments for patient-centered outcomes, and stakeholders may highly rate the need for such instruments. Measurement designs may not have been reviewed in the original review, but further CER trials may depend on the availability of adequate outcome measures. Therefore, it may be difficult to know whether this proposed gap has already been filled. The original study team may be able to determine from the background readings and title and abstract reviews whether certain study designs or research exists but was not included in the systematic review. However, some FRN teams might not have this background information if they were not authors of the original systematic review. Because substantial new systematic data collection and quality assessment of additional literature are not within the scope of the FRN process, the FRN team will not perform a detailed full text review and quality rating of additional studies. Exploring the existence of additional research with the diverse group of stakeholders may help determine if an evidence gap exists, with very limited examination of new literature. However, when it is not clear whether the proposed highly rated new research need is duplicative, this should be noted in the FRN report so that researchers considering this topic would be promoted to conduct a review of the literature to make sure that the research need has not already been addressed. Conversely, if an identified gap could be filled by RCTs, for example, but trials have been unable to accrue subjects because of recruitment difficulties, this concern should be included in the study design considerations text. The intent of the FRN process is for these to be practical considerations, based on both research theory and implementation issues.