# Introduction

This methods paper was commissioned by the Agency for Healthcare Research and Quality (AHRQ) as one of a series of papers addressing methods issues in the relatively new area of explicit discussion of future research needs (FRN) as part of comparative effectiveness research (CER). This paper is intended to reflect current and recommended practices for the AHRQ Evidence-based Practice Centers (EPCs); it represents initial guidance, as additional experience with future research needs may lead to modifications in the future. Other papers in this methods series on FRN in CER may be found on AHRQ’s Effective Health Care (EHC) Program Web site: www.effectivehealthcare.ahrq.gov/futureresearchneedsmethods.cfm.

## Comparative Effectiveness Research

CER is the “generation and synthesis of evidence that compares the benefits and harms of alternative methods to prevent, diagnose, treat, and monitor a clinical condition or to improve delivery of care. The purpose of CER is to assist consumers, clinicians, purchasers, and policymakers to make informed decisions that will improve care both at the individual and the population levels.”1 CER comprises a broad range of activities and types of study, encompassing systematic reviews, secondary data analyses, randomized controlled trials, prospective observational studies, health systems research, and dissemination of results to the public, providers, policymakers, and other key stakeholders. Key components of CER include comparisons between active treatments, policies, or diagnostic strategies and evidence from research conducted in settings similar to those in which most patients with a given condition are treated. The explicit nature of CER is demonstrated by the descriptions of proposed study questions through the PICOTS format, in which each key question is described using six dimensions: population, intervention, comparator treatment or test, outcomes assessed, time frame, and study setting.2

## Future Research Needs

Systematic reviews of focused clinical and policy questions reach conclusions whenever feasible and describe the strength of evidence (SOE) supporting those conclusions. However, many reviews find only low or insufficient SOE to address a given key question. Problems are often identified with the amount or quality of the literature examined, leading to an inability to address all of the components of the key study questions to sufficiently address the clinical and policy needs that led to the key questions. Gaps in the evidence remain. A common criticism of systematic reviews is that, although they generally contain a section describing the limitations of the research just reviewed, these limitations sections often are very general (e.g., “larger trials are needed”) and provide relatively little guidance to funders or the research community regarding the next study or series of studies needed to advance a given field.3 Yet a key, and to date underused, role of the systematic review process is to stimulate new research to address identified gaps in the literature.

With these FRN papers and accompanying methods papers, the AHRQ EPC Program distinguishes between the evidence gaps that are identified from within a systematic review and those that are prioritized and clearly defined as research needs by stakeholders based on their potential impact on practice or care. A more explicit and prioritized listing of research needs, with guidance regarding how to address those needs, could allow the impact of systematic reviews to be more fully realized and increase the pace of research to provide meaningful answers. The audience for FRN reports includes the research community, funders, policymakers, and advocacy groups. Reducing the time between synthesis of evidence, identification of FRNs, and initiation of studies to address those needs is urgently required in the current health care environment.

## The Future Research Needs Process

In the AHRQ EHC program, FRN documents are derived from systematic reviews of CER questions. The FRN document follows online publication of the systematic review and serves as a standalone document. Figure 1 shows the flow of an FRN project.

Figure 1 Flowchart of the FRN process

^a^ May include identification of additional evidence gaps.

^b^ Reduction through topic consolidation, preliminary prioritization, and consideration of ongoing research (duplication criteria).

^c^ Evidence gaps that address specific methods issues would not use the PICOTS framework.

^d^ May require iterative steps.

Figure 1 is a flow diagram of the future research needs process. Seven bulleted descriptions of each step begin at the top of the figure and are listed one below another. The seven steps are: 1) Systematic Review is Published with EPC determined Evidence Gaps; 2) Orientation of stakeholders to CER question, FRN process, and prioritization criteria (may include identification of additional evidence gaps); 3) Elaboration and consolidation of Evidence Gaps through iterative process with stakeholders (reduction through topic consolidation, preliminary prioritization, and consideration of ongoing research (duplication criteria)); 4) Transformation of Evidence Gaps into Research Questions using relevant framework (Evidence gaps that address specific methods issues would not use PICOTS framework); 5) Ranking of research questions by stakeholders (potential value criteria) resulting in Research Needs (may require iterative steps); 6) Addition of Study Design Considerations and Feasibility Issues; and 7) Publication of Future Research Needs Document.

Each FRN report begins by identifying a list of evidence gaps from the systematic review (in draft or final form), which may be augmented with input from a multidisciplinary panel of stakeholders familiar with both the research methods as well as the clinical and policy content of the systematic review. The EPC then works with the stakeholder group to elaborate and consolidate the evidence gaps, taking into consideration any ongoing or planned research that may already be addressing gaps. Potential research questions are then elaborated following the PICOTS framework with the exception of methodological questions, which may be organized differently.4 Once the questions have been formalized, they are given a final prioritization by the stakeholders according to potential value criteria. The final list of 4 to 12 high-priority FRNs with specific questions including PICOTS definition (as appropriate) and potential study designs is published in a final document intended for use by researchers and funders of research (Figure 1, Step 7).

## Scope of This Paper

This paper is one of a series of papers that provides recommendations and best practices on the steps in identifying and prioritizing FRNs. Other papers that address other steps in the FRN process will be posted as they are completed at www.effectivehealthcare.ahrq.gov/futureresearchneedsmethods.cfm.

Our paper proposes a method for composing the study design considerations portion of FRN reports. This portion discusses proposed research designs for addressing the high-priority research needs as determined using stakeholder input. Each proposed research design is accompanied by a discussion of advantages and disadvantages for using the approach. Here we present:

- a framework based on a standard taxonomy for study designs and criteria for evaluating the appropriateness of a study design to address a particular research need and
- criteria for evaluating each design: the advantages of the study design for producing a valid result; the resources needed and duration of the proposed study; the availability of data or ability to recruit; and ethical, legal, or social issues.

The study design discussions are intended to be considerations and not prescriptive to researchers or funders. This framework is intended to help FRN project teams consistently apply criteria to determine which study design may be most appropriate for each research question and provide suggestions for their rationale and presentation.