# Examples of Study Design Considerations

The examples that follow illustrate the team’s thinking about the content and format of demonstrating study design considerations within FRN reports. The first three are examples of a single FRN; the fourth example is a discussion of sample size issues. The examples are derived from the first series of EPC FRN reports; the needs have been reformatted to reflect the recommended presentation described in this paper. A tabular format is considered most succinct (Example 2; see Table 2). As discussed above, the descriptors of the study design considerations should be brief. Only one to three (rarely more) of the most feasible study designs should be presented; we believe it is redundant and potentially confusing to present iterations of why, for example, a cross-sectional study design is inappropriate as a means of filling an evidence gap related to treatment effectiveness. For some gaps, only an RCT might suffice and, therefore, only one study design presentation is appropriate. As discussed previously, the authors of the FRN report should encourage creativity and emphasize that these considerations are meant to be illustrative, not prescriptive. Further, advances in analytic methods may enable alternative study designs not anticipated by the FRN team. Additionally, the FRN project team should consider and discuss the lessons learned from studies included in the CER. A discussion of methodological weaknesses that limit the strength of available evidence could be used to support a suggestion that would prevent repeating previous mistakes. Methodological evidence gaps, if apparent, should also be addressed in the study design considerations.

Table 2 Comparison of study designs

Study Design Considerations | Randomized Trial | Nonrandomized Trial | Prospective Cohort
Description of design | Individual patients randomly assigned to planned vaginal or planned Cesarean at a predetermined period before delivery. | Individual practices assigned to protocols promoting a high use of planned Cesarean versus a low use of planned Cesarean delivery. | Individuals allowed to select either planned Cesarean or planned vaginal delivery; data collected on health status and delivery intent at a predetermined period before delivery, and continued data collection on changes in intent up to and through delivery.
Advantages of study design for producing a valid result | Although the design, if feasible, is likely to produce the most valid results, generalizability of a sample willing to be randomized on an issue imbued with personal preference and confounded by preexisting health factors is likely to be low. | The results of assigning practices will increase the generalizability of the results greatly but will sharply reduce the validity of the results. Another potential constraint to validity of results from nonrandom assignment of practices is that practices may cross over to greater or lesser promotion of planned Cesarean(s) over time. | Strong potential for confounding, but repeated measures of delivery intent may increase ability to control for confounding by indication. Good generalizability.
Resource use, size, and duration | Likely to require substantial resources to recruit sample large enough to evaluate rare neonatal outcomes. | Lower resource use than randomized studies but will require resources to ensure monitoring of fidelity to protocol. Recruitment of sufficient number of practices can be a constraint, so sample size considerations will continue to be an issue. | Low resource use other than data collection of intent and outcomes. Unlikely to have significant constraints on sample size.
Ethical, legal, and social issues | Significant ethical and legal issues with randomization. | Fewer ethical and legal issues in recruiting and assigning practices to a protocol than individuals. | No major ethical or legal issues.
Availability of data or ability to recruit | Poor. | Better than randomized trial, but challenges remain. | No major challenges to recruitment.

## Example 1 Narrative/Bulleted Text

Content area: Fixation of fractured hip: “Do certain procedures (e.g., internal fixation) work better than others for frail elder patients?”8

### Randomized Trial

- [underlined: Advantages of study design for producing a valid result]: A well-done RCT will produce the most convincing results and, if inclusion/exclusion criteria and setting are realistic, should be fairly generalizable.
- [underlined: Resource use, size, and duration]: An RCT has to be large, because the question compares active treatments and the effect size may be small and easily swamped by other causes of morbidity and mortality in this population. Duration depends on whether the trial focuses on peri-procedural complications and short-term outcomes or on the longer-term durability of different treatment options. In either case, the resource requirements will be large or very large, given that the effect size between the treatments might be modest.
- [underlined: Ethical issues]: As long as equipoise exists among the treatment options, ethical issues regarding enrollment should not be present. However, if the study includes patients with dementia, consent issues may occur.
- [underlined: Availability of data or ability to recruit]: Recruitment may be slow, because this is a subpopulation of the population of hip fracture patients, and it may be difficult to reach large numbers.

### Prospective Cohort Study

- [underlined: Advantages of study design for producing a valid result]: Although concern for selection bias and unmeasured confounders will always exist, the prospective design allows data for the most relevant known confounders to be collected and controlled for. Therefore, while the results will not be as definitive as an RCT, they could be informative.
- [underlined: Resource use, size, and duration]: This type of study still requires a large size because of potentially small treatment effects, but it would likely be less expensive than an RCT.
- [underlined: Ethical, legal, and social issues]: The main ethical issue is consent in the case of patients with dementia; however, because choice of treatment is not involved, it may be of less concern.
- [underlined: Availability of data or ability to recruit]: Recruiting patients for this design should be easier than for an RCT.

### Retrospective Cohort Study

- [underlined: Advantages of study design for producing a valid result]: Significant risk of selection bias exists, and there is less ability to control for confounders than in a prospective cohort study because key variables may not be collected. However, this design could be sufficient for hypothesis generation that could then be used to design a more focused RCT.
- [underlined: Resource use, size, and duration]: A retrospective cohort study design has the potential to be considerably faster and less expensive than either an RCT or a prospective cohort study.
- [underlined: Ethical, legal, and social issues]: Confidentiality and Health Insurance Portability and Account (HIPAA)^†^ issues may arise when diverse databases are linked without specific patient consent.
- [underlined: Availability of data or ability to recruit]: Recruiting is very feasible; the main concern is selection bias, depending on the source of the secondary data, and missing variables. Negotiations with the holders of the secondary data may take significant time.

## Example 2 Table

Content area: Elective Cesarean section compared with planned vaginal delivery in healthy women. “What is the comparative effectiveness of planned Cesarean delivery versus planned vaginal delivery on maternal and neonatal outcomes?”9

## Example 3 Process or Methods Considerations

Content area: Treatment of prostate carcinoma. “Facilitate future research on potential biomarkers to identity patients whose disease is likely to be aggressive.”10

Context: Although many efforts have been made to predict which patients with localized prostate cancer have aggressive disease, existing tools are inadequate to predict which patient to treat with any high degree of accuracy. With the emergence of biomarkers in other diseases, such as breast cancer, that have both prognostic and predictive power, the search continues to identify biomarkers that can predict which patients with prostate cancer face a poorer prognosis and may benefit to a greater degree from immediate treatment. Although a number of biomarkers have been explored to date with limited success, biomarkers continue to have a potentially important role.

Proposed research design: Establish biospecimen repositories with clinical data on diagnosis, treatment, and follow-up.

Study design considerations:

- [underlined: Advantages of study design for producing a valid result]: Biospecimen repositories create the resources needed to test the use of novel biomarkers in the future, while providing long-term data on outcomes that would take a long time to collect. Such repositories are being established for other studies, such as the ProtecT trial in the United Kingdom. In addition, given the differences in treatment regimens, populations, and possibly outcomes across studies, biospecimens from different trials might help address alternative hypotheses. The National Cancer Institute is establishing methods for each step of the process for creating and maintaining biospecimen repositories.
- [underlined: Resource use, size, and duration]: Although expensive to create and maintain, additional repositories will allow more biomarker testing, particularly because tissue specimens are finite. The administrative complexity of tracking specimens and their use is substantial, and ongoing infrastructural funding is essential.
- [underlined: Ability to recruit]: At the time of biopsy or surgery, patients could be consented for participation. Given that tissue is obtained as part of the procedure, this should be straightforward.
- [underlined: Ethical, legal, and social issues]: Biorepositories require extensive documentation of their policies regarding tracking and use of specimens. The proposed revisions to the Federal Department of Health and Human Services (HHS) Common Rule may partially address these issues. ‡ Significant planning will be needed.

## Example 4 Sample Size Calculations To Inform Feasibility of Future RCTs

Content area: Coronary artery stenting compared with coronary artery bypass surgery.

Percutaneous coronary interventions (PCI) with or without stents and coronary artery bypass graft surgery (CABG) are clinically relevant treatment options for many patients with coronary artery disease (CAD). In assessing this topic, it was deemed that an important gap pertained to the comparative effectiveness and safety of the interventions in the elderly (aged 75 or older).11

But exactly what merits further study? A focused value-of-information analysis helped clarify the group of parameters that would most inform the decision of choosing between PCI and CABG in the elderly. The analysis suggested that the relative safety of the interventions (i.e., relative effects on post-intervention complications) was more important than, for example, the absolute frequency of adverse events in the postintervention. As per descriptions above, a possible design to address relative effects of treatments is an RCT.

Is it realistic to consider a new RCT to compare PCI versus CABG? One can perform high-level sample size calculations. The biggest trials in the field enrolled approximately 2,500 patients, which serves as an indication of a large feasible RCT. Figure 2 shows power attained over a range of sample sizes for various control rate values over a mean followup of 3 or 5 years (see legend for details). Power increases with sample size, with control rate, and with length of followup. Over 5 years of followup, a study of approximately 2,500 patients would attain 80 to 90 percent power to find a relative effect of 0.80 only if it chooses an outcome that has at least a 30 percent control rate. This means a composite outcome. To get average followup duration of approximately 5 years, a trial would have to go on for 6 to 8 years at least (see legend).

Figure 2 Power calculations for superiority RCTs for various 5-year primary event rates in the comparator arm11

Plotted are power calculations for six different 5-year primary event rates in the comparator arm (5%, 10%, 15%, 20%, 30%, and 40%, as shown next to each line in each panel). The calculations are for a two-sided chi-squared test at the 0.05 level of significance, and assuming a constant annual event rate, a true relative effect of 0.80 favoring the intervention arm, an allocation ratio of 1:1, no loss to followup, no crossover between treatments, and no sequential monitoring. The gray area denotes sample sizes larger than the biggest existing RCTs on this question (>2,500 patients total). The red horizontal line stands for 90% power. Note that to get average followup duration of approximately 5 years, a trial would have to go on for 6 to 8 years. We calculate this assuming a minimum followup of 2.5 years, a patient recruitment period of 5 years, and a constant recruitment rate. In reality, the total sample size would have to be even larger than what is shown in the horizontal axis, as there will be loss to followup and there may also be adjustments for sequential monitoring.

Plotted are power calculations for six different 5-year primary event rates in the comparator arm (5%, 10%, 15%, 20%, 30%, and 40%, as shown next to each line in each panel). The calculations are for a two-sided chi-squared test at the 0.05 level of significance, and assuming a constant annual event rate, a true relative effect of 0.80 favoring the intervention arm, an allocation ratio of 1:1, no loss to follow-up, no crossover between treatments, and no sequential monitoring. The gray area denotes sample sizes larger than the biggest existing RCTs on this question (>2,500 patients total). The red horizontal line stands for 90% power. Note that to get average follow-up duration of approximately 5 years, a trial would have to go on for 6 to 8 years. We calculate this assuming a minimum follow-up of 2.5 years, a patient recruitment period of 5 years, and a constant recruitment rate. In reality, the total sample size would have to be even larger than what is shown in the horizontal axis, as there will be loss to follow-up and there may also be adjustments for sequential monitoring.

Therefore, de novo RCTs are feasible but would likely require resources comparable to recent large RCTs. The above calculations are generic and thus apply to any subset of patients with heart disease. For example, in middle-aged patients with two vessel disease, one would have to define a composite outcome of death or myocardial infarction or other cardiac events to attain a high event control rate and, thus, high power to detect a significant difference. By contrast, in the subpopulation of elderly patients (e.g., older than 75 years), where mortality rates can be high enough, one may be able to attain high statistical power for the outcome of death alone.

† The Health Insurance Portability and Accountability Act of 1996 (HIPAA) Privacy and Security Rules

‡ The Common Rule is located at 45 CFR part 46, subpart A, and described at: http://www.hhs.gov/ohrp/humansubjects/commonrule/index.html.