# Criteria for Considering Study Designs

To provide additional guidance for using this categorization scheme for the consideration of study designs for FRN projects, we have added brief summaries of the basic dimensions that should be considered when discussing different possible study designs. It is hoped that the process of reviewing and synthesizing the studies to date for a particular topic will give the reviewers some insight into how these criteria might affect the feasibility or utility of additional studies. The first criterion is the ability of the design to produce a valid result; the latter three criteria are elements of determining the feasibility of conducting a study. In recommending one or two study designs, FRN teams will need to consider each of these issues, balancing them against one another. Although a given study design may be optimal for producing a valid result, feasibility issues are critical in choosing a study design. An optimal study design that, for example, fails to recruit adequate numbers of subjects or has a very high dropout rate will not add to our knowledge of a field. These descriptors and comments are generic and may need to be modified or added to for each given FRN exercise, given the clinical and policy context of the condition under consideration. In developing these summaries, we used the following working definitions.

## Advantages of Study Design for Producing a Valid Result

This dimension allows for exploration of how study design contributes to validity and how the importance of different types of validity may vary according to the question and the body of previous evidence. The main advantage of the study design in providing a valid result (the greatest validity in answering a given question) is avoiding systematic error. In CER, additional advantages may include the ability to rapidly conduct a study in a policy-relevant environment and address issues of the effectiveness, as opposed to efficacy, of an intervention or diagnostic test.

Given that the context is effectiveness research, generalizability or external validity should be included in these study design considerations. Although issues of internal validity are often specific to the study design, generalizability may depend on the clinical condition under study, the settings in which it is treated, and the populations affected.

### Resource Use, Size, and Duration

This dimension describes the magnitude of resources required to achieve a meaningful answer to the research question using this study design. Although this dimension will often translate into higher versus lower cost, resource use could also include the opportunity costs of practice resources or investigator time. Within study designs, costs are not fixed. Randomized controlled trials (RCTs) can be very expensive, but large, simple trials have also been conducted for relatively modest costs; trials requiring only a short duration (some infectious disease trials) are less expensive than chronic disease trials, which may need to observe subjects for years. The size of a study depends on a variety of factors, including the expected number of outcome events occurring or, in the case of a nondichotomous outcome event, the precision with which a scale can be assessed. The duration of a study depends on the anticipated accrual of recruited subjects, the incidence of outcome events, and the natural history of the condition studied.

### Availability of Data and Ability To Recruit

This dimension assesses the likelihood that the study design will be able to achieve the basic inputs (data or patients) required for launch. Data and recruitment are partially dependent on study design and partially dependent on the content area. For example, subjects are generally much easier to recruit into observational studies than intervention trials. FRN researchers may know of already existing secondary databases that might address an identified evidence gap.

### Ethical, Legal, and Social Issues

This dimension deals with the external issues that could affect the feasibility or desirability of different study designs. Potential problems with ethical conduct of research are likely to vary depending on the content of the proposed measurement and intervention and the current standard of care, and may not be a consistent feature of a particular study design.

These guidelines should be applied with flexibility to considerations of study designs for FRNs. The advantages and disadvantages of a study design may change depending on the study question or the setting. The resources required for a study design depend on the intervention proposed. The features of a specific FRN may make some study designs better suited under those particular circumstances. Considerations should include an understanding of the context of the research, including the condition or health policy being investigated, the existing body of evidence, and potential utility and quality of the data gained through different study designs. The urgency with which an answer to the research question is needed may be an additional ethical consideration in prioritization of research needs.