# Conclusions

The incorporation of study design considerations into FRN documents provides an important addition to the priority-setting function of the reports. The summary guidance from the workgroup follows:

- Use of common terminology for study designs can aid in communication regarding FRNs. Such terminology can, of course, be modified when appropriate.
- Each high-priority research need may be addressed with one or more than one potential study design.
- EPC teams should incorporate brief discussions of study design considerations for the highest priority research needs into all FRN reports.
- Considerations for recommendation of a study design include ability of the study design to produce a valid result, as well as feasibility considerations such as resources needed; availability of data or ability to recruit and retain subjects; and ethical, legal, and social considerations.
- The PICOTS format can assist in making aspects of the FRN and the study design explicit but may not be appropriate for some types of study designs, such as methods enhancements.
- Some types of study designs that may be proposed, such as methods development, may not have been systematically reviewed in the original work, and prior to initiating the research project, investigators should determine whether the new work is duplicative.
- Sample size or power calculations may be helpful in considering the feasibility of future studies.