# Common Terminology for Study Designs

An initial task is to categorize study designs, so that the EPCs will be consistent in their terminology across reports and to use common descriptors of the potential advantages and disadvantages of each study design when applied to a given FRN. The following categories of studies and their descriptions are derived from the AHRQ report “Developing and Testing a Tool for the Classification of Study Designs in Systematic Reviews of Interventions and Exposures” published in December 2010.^7^ We have added several additional considerations of study types that might be useful in study design consideration discussions. Although these descriptions are consistent with other study design categorization systems, the authors of the report found that the agreement across raters (kappa statistics) in classifying studies was fair at best.7 Researchers from different disciplines (epidemiology, health policy, etc.) may use differing terms to describe the same study design, and a more consistent terminology will assist communication across disciplines and reports. Different disciplines may use differing terminology to describe the similar study designs. The list below is not intended to be comprehensive and modifications in design and terminology will be appropriate in some circumstances. The terms below do, however, represent a common point of communication prior to adaptation to each study question. The study design terms used in this discussion are listed in Table 1, and descriptions are provided in Appendix A.

Table 1 Study design terms

Terms
A. Randomized controlled trial (RCT) | H. Nested case-control study
B. Nonrandomized comparative trial | I. Case-control study
C. Prospective cohort study | J. Interrupted time series (without a comparison group)
D. Retrospective cohort study | K. Before-after study
E. Interrupted time series with comparison group | L. Cross-sectional study
F. Controlled before-after study | M. Noncomparative study
G. Nonconcurrent cohort study | N. Other considerations: Meta-analysis of individual participant data Modeling Additional systematic review