# Appendix A Taxonomy for Study Designs^4^

The initial descriptive text following each design name comes from the Alberta report,7 the subsequent text regarding design validity, resource use, recruitment and available data, and ethical, legal, and social issues is from the authors of the current report. The points raised for each dimension are intended as a starting point to inspire discussion, rather than a set recipe for evaluation.

## A Randomized Controlled Trial (RCT)

An RCT is a study designed to test the efficacy of an intervention on an individual, a group of individuals, or clusters (e.g., classrooms, communities). Individuals or clusters are randomly allocated to receive an intervention or control/comparison (e.g., placebo or another intervention) and are followed prospectively to assess differences in outcomes. The unit of analysis is the individual, group of individuals, or the cluster, as appropriate. Many CER interventions addressed by EPC’s involve interventions at the level of the provider or the practice through which patients are clustered within another unit. Randomization among a relatively small number of clusters requires planning so as to address the need for balance in baseline characteristics and address sample size considerations in the clustered design. Variations in treatment assignment and measurement produce different types of studies including factorial, crossover, parallel, stepped wedge and Solomon four-group, and adaptive designs.7

Advantages of study design for producing a valid result: An RCT is the best method to control for selection bias and both measured and unmeasured differences between groups at baseline, but these benefits may come at the cost of generalizability. Pragmatic trial strategies may be appropriate to address this challenge in some cases. At the same time, the RCTs of some questions (particularly long-term outcomes) may be vulnerable to crossover, leading to problems in interpretation of “intention to treat” analyses.

Resource use, size, and duration: Generally, RCTs are high cost in dollars and investigator time, although some types of trial designs, which involve less data collection from subjects than other types of designs, may reduce the resources needed. Study duration will depend on the underlying condition assessed. For example, duration of acute infectious diseases may require only a brief followup. As these are prospective studies, duration is longer than retrospective studies. Study size will depend on the effect size being sought between intervention and comparator groups.

Availability of data or ability to recruit: This factor varies by topic. Even if the research community believes that equipoise exists, patients may be reluctant to accept randomization for some interventions or medical conditions.

Ethical, legal, and social issues: Concerns may occur when treatment is assigned though random allocation. Patients and treating clinicians must perceive equipoise across tests or treatments when invited to participate in a research study. Careful stopping and reporting rules will be important if evidence of significant benefit or harm is found. RCTs are typically performed when there is equipoise on the optimal treatment. Equipoise is topic-specific: most often, it refers to expected patient health-relevant outcomes (clinical equipoise), but it may also refer to optimal resource allocation and other considerations.

## B Nonrandomized Comparative Trial

A nonrandomized comparative trial is a study in which individuals or groups of individuals (e.g., community, classroom) are assigned to the intervention or control by a method that is not random (e.g., date of birth, date of admission, judgment of the investigator). Individuals or groups are followed prospectively to assess differences in the outcome(s) of interest. The unit of analysis is the individual or the group, as appropriate.7

Advantages of study design for producing a valid result: Selection bias by subjects will be partially controlled for since the researchers will assign treatment, although the groups may not be balanced at baseline. Prospective design allows better assessment of baseline status. This design might be appropriate when allocation is ‘clustered’ at the unit of intervention, such as practices, health care facilities or geographic areas. In such situations, purposive sampling may be the best way to assure balancing of covariates between intervention and comparator groups. Some rules for assignment, such as birth date or date of clinical visit, may be susceptible to ‘gaming.’ When study duration is long, crossover may occur, leading to difficulty in interpretation according to ‘intention to treat’ analyses.

Resource use, size, and duration: Resources needed are generally high, but can be less expensive than randomized trials. Study duration will depend on the underlying condition being assessed. For example, duration of acute infectious diseases may require only a brief follow-up. Because these are prospective studies, duration is longer than retrospective studies. Size will depend on the effect size being sought between intervention and comparator groups.

Availability of data or ability to recruit: Acceptability to potential subjects is better than RCTs in which a group is assigned at random. One disadvantage is that subjects may be less willing to accept an assignment as opposed to maintaining choice.

Ethical, legal, and social issues: Concerns may occur when treatment is assigned by investigators. Patients and treating clinicians must perceive equipoise across tests or treatments when invited to participate in a research study. Careful stopping and reporting rules will be important if evidence of significant benefit or harm is found.

## C Prospective Cohort Study

In a prospective cohort study, individuals in the group without the outcome(s) of interest (e.g., disease) are classified according to exposure status at baseline (exposed or unexposed) and then are followed over time to determine if the development of the outcome of interest is different in the exposed and unexposed groups. 7

Advantages of study design for producing a valid result: This type of study may be the optimal design when treatment or exposure cannot ethically or practically be assigned. Baseline characteristics can be measured, but may not be balanced between the two groups. If sample size is large, this design may be the best method to assess subgroup effect or incidence of harms. Statistical techniques to adjust for baseline differences may not completely control for potential bias. Crossover may occur, especially in longer duration observation.

Resource use, size, and duration: Resources needed are moderate to high; similar to a prospective trial, although less than a study design in which treatment is assigned. Size and duration will depend on the natural history of the condition under study, and the effect size or incidence of harm thought to be clinically important.

Availability of data or ability to recruit: Acceptability to potential subjects is better than designs in which treatment is assigned. The ability to recruit may depend on the respondent burden.

Ethical, legal, and social issues: Since patients and/or providers select the treatment, few ethical issues are likely to occur, although careful stopping and reporting rules will be important if evidence of significant benefit or harm is found.

## D Retrospective Cohort Study

In a retrospective cohort study, a group of individuals is identified by common features that were determined in the past. The group is usually assembled using available data sources (e.g., administrative data). Individuals are classified according to exposure status (exposed or unexposed) at the time the group existed and are followed up to a prespecified endpoint to determine if the development of the outcome of interest is different in the exposed or unexposed groups.7

Advantages of study design for producing a valid result: Subjects are followed over time. The duration of the study is short since it is retrospective. Baseline measures are not prospectively assessed; the researchers must accept the data already collected, so key variables may not be added. Significant risk of selection bias exists, since subjects either choose their treatment or it is assigned by a health care provider. The generalizability of the study result will depend on the population sampled.

Resource use, size, and duration: Since these studies often use data already collected, they are much less resource intensive than studies employing prospective data collection. The duration of the study is short relative to studies involving primary data collection. However, such studies often take somewhat longer than envisioned. Sample size may be very large given the increasing availability of large administrative claims and electronic medical record (EMR) databases.

Availability of data or ability to recruit: Recruiting is very feasible; the main concern is selection bias, depending on the source of the secondary data, and missing variables. Negotiations with the holders of the secondary data may take significant time.

Ethical, legal, and social issues: Confidentiality and HIPAA^5^ issues may arise when diverse databases are linked without specific patient consent.

## E Interrupted Time Series With Comparison Group

In this type of study, multiple observations over time are “interrupted” by an intervention or exposure, and two series are examined (one is a comparison group). At least three observations before and at least three observations after the intervention or exposure must take place for each group. The investigator(s) does not assign or have control over the intervention/exposure, which may be an environmental variable (e.g., airborne toxin) or administrative assignment (e.g., seatbelt legislation, educational program, service delivery model) but does control the timing of the measurement and the variables being measured.7

Advantages of study design for producing a valid result: This type of study may be the optimal method for evaluating some policy-level interventions (such as legislation or an insurance policy change) for which assignment cannot practically be performed. There may be differences in both measured and unmeasured characteristics at baseline. Other co-interventions may occur in the health care environment, leading to difficulties in attribution of the observed change in outcome to the intervention of interest. However, the investigator may not have any control over the number or timing of observation points.

Resource use, size, and duration: Resources needed are generally modest, depending on the amount of new data that needs to be collected. The duration of the study is short relative to studies involving primary data collection. However, such studies may often take longer than planned. Sample size can be very large given the increasing availability of relatively inexpensive large administrative claims and EMR databases.

Availability of data or ability to recruit: Recruiting is very feasible, since the study is conducted as a naturally occurring experiment. Negotiations with the holders of the secondary data may take significant time.

Ethical, legal, and social issues: Such issues should be minimal, although some issues regarding HIPAA and data use agreements may be relevant.

## F Controlled Before–After Study

In a controlled before-after study, the outcome(s) of interest is measured both before and after the intervention or exposure in two or more groups of individuals. In this study design the study group receives the intervention or exposure and the comparison group(s) does not. This type of study includes interventions that may be in the control of the investigator (e.g., a surgical procedure) as well as interventions that may be an environmental variable (e.g., airborne toxin) or administrative assignment (e.g., seatbelt legislation). In all cases the investigator(s) controls the timing of the measurement and the variables being measured.7

Advantages of study design for producing a valid result: This type of study may provide greater validity than an interrupted time series study, which is purely observational. This study design may provide better assessment of baseline variables for assessment of confounding. The study groups are likely to be unbalanced at baseline, and statistical measures to control for differences in group characteristics are likely to be only partially successful. Residual confounding will likely be present.

Resource use, size, and duration: Resources needed are somewhat greater than for interrupted time series design, since consent will be required for many interventions. Size of the study sample may range from small to very large. Small studies may involve one or a few providers or practices and may approximate case studies. Duration will depend on the outcomes selected and the anticipated lag between the intervention and the expected clinical outcome.

Availability of data or ability to recruit: Recruiting is fairly feasible, but some subjects may refuse to participate. This design may be the best way to study some interventions where randomization may not be acceptable to providers or patients.

Ethical, legal, and social issues: If the providers or patients are not at equipoise, ethical issues may be pertinent if individuals are perceived as not receiving efficacious care.

## G Nonconcurrent Cohort Study

In a nonconcurrent cohort study, two or more groups of individuals are identified on the basis of common features at different time points. Individuals in each group are classified according to exposure status (exposed or unexposed) at the time the groups existed or were created. They are followed to determine if the development of the outcome of interest is different in the exposed or unexposed groups.7

Advantages of study design for producing a valid result: Selection bias and group differences in patient characteristics may lead to residual confounding. The ‘historical controls’ may have differences in either baseline characteristics, or, commonly, differences in co-interventions which may be difficult to adjust for statistically.

Resource use, size, and duration: The resources needed are relatively low compared with randomized or controlled trial designs, but greater than entirely retrospective studies. The study size may range from small to very large, depending on the research question and the availability of data. Duration will depend on the outcomes selected and the anticipated lag between the intervention and the expected clinical outcome.

Availability of data or ability to recruit: Good. Patients and providers choose the treatments so acceptance will be high. New data collection may or may not be needed. This study design generally uses existing data; negotiation with the owner of the data regarding access may take time.

Ethical, legal, and social issues: Such issues should be minimal, since the exposure is not being assigned by the investigator. The usual ethical issues of informing subjects of potential benefits and harms will apply.

## H Nested Case Control Study

In a nested case control study, exposed and control subjects are drawn from the population of a prospective cohort study. Baseline data are obtained at the time the population is identified; the population is then followed over a period of time. The study is then carried out using persons in whom the disease or outcome has developed and a sample of those who have not developed the outcome of interest (controls).7

Advantages of study design for producing a valid result: This study design is most appropriate for etiologic studies. It uses existing data, and is relatively quick to conduct. It has some advantages over the usual case-control study, since the assessment of subject characteristics is generally reliable within the original cohort study, which may use primary data collection. The case control study design does, however, have multiple threats to causal inference. The original cohort should be assessed regarding its representativeness for the population of interest.

Resource use, size, and duration: Resources needed are low. The size of the study is generally modest, since it is nested within an existing cohort or other prospective study. The duration of the study is relatively brief since the investigators are generally working from previously collected data.

Availability of data or ability to recruit: High, since researchers are often sampling using already-collected data.

Ethical, legal, and social issues: Such issues should be minimal, since the study is observational.

## I Case Control Study

In a case control study, participants are selected based on the known outcome(s) of interest (e.g., disease, injury). Exposure status is then collected based on the participants’ past experiences. Exposure status is compared between the two (or more) groups: those who have the outcome of interest and those who do not have the outcome of interest (controls). This is a retrospective study that collects data on events that have already occurred.7

Advantages of study design for producing a valid result: This study design is most appropriate for etiologic studies, and is relatively quick to conduct. The case control study does have multiple threats to causal inference inherent to the study design. Choice of controls as representing those at risk for the outcome of interest is key to validity.

Resource use, size, and duration: Few resources are needed. The size of case control studies is variable, and in part depends on the number of controls selected for each case. Sample sizes are generally modest. The duration is relatively brief since the study design is retrospective.

Availability of data or ability to recruit: High, since researchers are often sampling from already collected data.

Ethical, legal, and social issues: Such issues should be minimal, since the study is observational.

## J Interrupted Time Series (Without a Comparison Group)

In this type of study, multiple observations over time are “interrupted” by an intervention or exposure. There must be at least three observations before the intervention and at least three observations after the intervention; otherwise, the study is considered a before-after study. The investigator(s) does not assign or have control over the intervention/exposure, which may be an environmental variable (e.g., airborne toxin) or administrative assignment (e.g., seatbelt legislation, educational program, service delivery model) but does have control over the timing of the measurement and the variables being measured.7

Advantages of study design for producing a valid result: This study design involves observation of a natural experiment. The changes observed may be difficult to differentiate from secular trend in occurrence of the outcome due to factors other than the variable of interest. No comparison group is present, limiting its utility in CER.

Resource use, size, and duration: Resources needed are relatively low. Study size can be small to large, depending on the intervention and the availability of data. Duration of the study will depend on the expected accrual of outcome events and the lag between the intervention and outcomes.

Availability of data or ability to recruit: High; generally uses already collected administrative or, in the future, EMR data.

Ethical, legal, and social issues: Such issues should be minimal, since the study is observational. There may be issues regarding data use agreements or HIPAA issues, but data can generally be appropriately de-identified to minimize risk of inappropriate disclosure.

## K Before–After Study

This is a study of an intervention or exposure in which the investigator(s) compares the outcome(s) of interest both before and after the intervention in the same group of individuals. This includes interventions that may be in the control of the investigator (e.g., a surgical procedure) as well as interventions that may be an environmental variable (e.g., airborne toxin) or administrative assignment (e.g., seatbelt legislation). In all cases the investigator(s) controls the timing of the measurement and the variables being measured.7

Advantages of study design for producing a valid result: This study has a simple design, similar to a case series study of an intervention. It occurs in a naturalistic setting and may have high generalizability. It may be difficult or impossible to attribute causal inference to the intervention since there is no comparison group. Natural history of the condition may be unknown.

Resource use, size, and duration: Resources needed are generally low, but depend on the cost of measurement. Study size may be small or large, depending on the intervention or the availability of data. Duration of the study will depend on the expected accrual of outcome events and the lag between the intervention and outcomes.

Availability of data or ability to recruit: High.

Ethical, legal, and social issues: Such issues should be minimal, since patient and provider select the treatment.

## L Cross-Sectional Study

In a cross-sectional study, both the exposure and the outcome status in a target population are assessed concurrently, that is, at the same point in time or during a brief period of time. The temporal sequence of cause and effect cannot necessarily be determined. They are most commonly used to assess prevalence. Data collection is commonly done by using a survey.7

Advantages of study design for producing a valid result: This design may be highly generalizable to the population of interest, but one cannot infer causation to an intervention.

Resource use, size, and duration: Moderate resources are needed, but significant effort may be required to generate generalizable samples of the population. The sample size may range from small to large, depending on the study question and the expected incidence of the condition or care utilization being studied.

Availability of data or ability to recruit: High, although response rates on surveys have been lower recently due to use of cell phones and caller identification.

Ethical, legal, and social issues: Such issues should be minimal to none; no intervention is involved. Confidentiality may be an issue for sensitive issues (HIV, mental health, etc.).

## M Noncomparative Study

Examples of this design include:

- A study that presents a description of a single patient or participant. Studies are usually retrospective and typically describe the manifestations, clinical course, and prognosis of the individual.
- A study that describes the experience of a group of patients with a similar diagnosis and/or treatment. Studies are usually retrospective and typically describe the manifestations, clinical course, and prognosis of a condition.
- A study in which data are collected at a series of points in time on the same population to observe trends in the outcome(s) of interest.7

Advantages of study design for producing a valid result: This type of design may describe a new or unique condition or intervention. The study is hypothesis generating rather than testing. Generally, one is unable to infer cause. Generalizability may be poor if the patients or setting are different from those in which patients with the condition of interest are usually seen. No comparison group is involved, making the utility of the study design in CER difficult.

Resource use, size, and duration: Resources needed are low. The sample size is generally small, since the study involves description of single or several subjects. Study duration is short and the data collection is often retrospective.

Availability of data or ability to recruit: Good, generally derived from existing medical record or administrative data.

Ethical, legal, and social issues: Such issues should be minimal; treatment is selected by patients and providers.

## N Additional Considerations

Meta-analysis of individual participant data, modeling, and additional systematic reviews of group data are additional analyses that do not necessitate collection of additional primary data. They can be reasonable choices for addressing FRNs, for informing choices between possible future studies, or for informing the planning of a definitive future study.

Meta-analysis of individual participant data (MIPD). In a meta-analysis of individual participant data (MIPD), data from existing studies are brought together using harmonized definitions, and reanalyzed according to a prespecified protocol. When individual participant data are available, outcome and exposure definitions can be standardized and much more powerful analyses can be used. A major advantage over a meta-analysis of group data is the ability to examine patient-level modifiers of the treatment effect, i.e., patient-level factors such as age, sex, and disease severity indices.

An MIPD can take longer to complete than an analysis of a readily available dataset from a single study. Logistical complications include, but are not limited to, identification of data sources, convincing investigators to participate, standardizing definitions of interventions and outcomes, complying with HIPAA, and harmonizing definitions of exposures and outcomes across datasets.

We maintain that if an MIPD is feasible, it should be considered as a possible method for studying questions on clinical heterogeneity in a timely manner. There are several examples of MIPDs that have generated answers to important questions.12, 13

Modeling. Modeling includes quantitative decision and economic (cost-effectiveness, cost-utility, and value of information) analysis. Many evidence gaps can be reasonably explored with modeling approaches. An example is the assessment of screening programs with respect to clinical outcomes. Even if one considers a single test, e.g., screening colonoscopy for preventing colorectal cancer, there are many choices regarding the age to start screening, how often to screen, and the age to stop screening. Studying a large number of screening schedules is impossible in an RCT—it may be difficult to study even two. Modeling can help explore which schedules are completely suboptimal and do not merit further study. It can also assist in determining which screening schedules are expected to be better, given the currently available information. Indeed, the United States Preventive Services Task Force took into account insights gained from modeling in formulating their screening recommendations for colorectal and breast cancer. Scrutiny at the level of comparisons among many screening schedules and with no screening is impossible without simulation modeling.

Additional Systematic Reviews. Evidence gaps and FRNs are derived from a systematic review, of course, and it may seem redundant that a systematic review would be recommended as a research need derived from a systematic review. However, a subanalysis that may have been out of scope of the original review, or derived from the review key questions but not assessed in the parent systematic review, could be considered an evidence gap. However, if the proposed evidence gap is conceptually quite far from the original key questions covered in the parent systematic review, then the scope of the FRN gaps identification would expand dramatically and potentially lose focus.

## O Additional Concepts

The terms in Table A-1 are derived from the Alberta report, and are commonly used in association with the study designs discussed above.7

Table A-1 Terms associated with study designs

Term | Description
Cluster | The term cluster refers to a unit of allocation or analysis in a clinical trial. Examples of clusters include hospitals, schools, neighborhoods, or entire communities.
Cluster randomized controlled trials | Synonym: community trial; group randomized trial. A randomized controlled trial in which the units of randomization and analysis are groups of people or communities (e.g., classroom, hospital, town). Typically, several communities receive the intervention and several different communities serve as controls.
Cohort | The term cohort refers to a group of individuals (or other organizational units) who have a common feature when they are assembled (e.g., birth year, place of employment, medical condition, place or time period of medical treatment) and are followed over time. They can be followed prospectively or examined retrospectively.
Experimental study | A type of study in which investigators directly control the timing, course, and assignment of the intervention. Experimental studies investigate an intervention to determine its effect on the outcome(s) of interest. In an experimental study a population is selected to receive a specific intervention, the effects of which are measured by comparing the outcomes in the experimental group with the outcomes of a control group that has received another intervention or placebo. Examples include randomized controlled trial, cluster randomized controlled trial, nonrandomized trial, n-of-one trial.
Observational study | A study in which the investigator(s) does not control the exposure/ intervention status of study participants (i.e., the assignment of the intervention or exposure of interest is not under the control of the investigator(s)). The simplest form of observational study is the case report or case series, which describes the clinical course of individuals with a particular condition or diagnosis. Observational studies include descriptive and analytic studies.
Quasi-experimental study | A type of study in which the investigator(s) evaluates the effect of an intervention but does not fully control the timing, course, or allocation of the intervention. They are often used when it is not possible to conduct a true experimental study.

4 Citations in this appendix are to the report‘s main reference list.

5 The Health Insurance Portability and Accountability Act of 1996 (HIPAA) Privacy and Security Rules