# Acknowledgments

The authors gratefully acknowledge the following individuals for their assistance with this manuscript: Roberta Wines, M.P.H., Research Associate at the University of North Carolina Chapel Hill Cecil G. Sheps Center for Health Services Research; Sharon Barrell, editor, RTI International; and Loraine Monroe, publications specialist, RTI International.