# Results

## Organization of Results

The results chapter presents results for KQ 1 first, followed by results for KQ 2. KQ 1 asks about the impact of EPC reports on future research. We present results for the literacy and health outcomes case study first, followed by the case study on omega-3 and CVD. As noted earlier, the latter case study includes two reports, but we do not provide completely parallel results for both reports: update search results were available only for the Balk et al. report.14 In keeping with our logic model, we distinguish among inputs, outputs, short-term outcomes, medium-term, and long-term outcomes to answer KQ 1 for each case study. For each type of outcome, we summarize the evidence on specific outcomes, using a variety of indicators and data sources (as detailed in Table 1). Our results for KQ 2 draw on qualitative evidence on barriers and facilitators to impact. KQ 2 summarizes themes across case studies and different lengths of outcomes to identify facilitators and barriers associated with the EPC reports that may modify their impact on future research.

## Impact of EPC Reports (KQ 1): The Literacy and Health Outcomes Case Study

Inputs. The American Medical Association (AMA) requested a report on literacy and health outcomes; AHRQ funded it. Principal authors included systematic review expert Nancy Berkman, Ph.D., of RTI International, and substantive experts Darren DeWalt, M.D., M.P.H., and Michael Pignone, M.D., M.P.H. of UNC.

Outputs. In January 2004, AHRQ released the report on literacy and health outcomes. The report prompted production of two journal articles that appeared in 2004 and 2005;^23,24^ the first authors were DeWalt and Pignone, respectively. DeWalt and Pignone also published editorials, including “Reading is Fundamental: the Relationship between Literacy and Health” in the 2005 Archives of Internal Medicine25 and “Literacy and Health Outcomes: Is Adherence the Missing Link?” in the 2006 Journal of General Internal Medicine.26

Short-term impact: Increased awareness of issues. Our analysis of the short-term impact of this report comes from several sources: evidence of citation of the report through searches from the updated reports, ISI Web of Science, and PubMed Central; dissemination through downloads and orders of the AHRQ report; qualitative reports of media interest; and heightened collaboration in the field.

Citation of the report. Our analysis of the literature from the health literacy update report suggests widespread citation of the 2004 report (Appendix D). Of 177 articles identified through the update search, nine had been published before the report and, therefore, could not have been influenced by the report. More than one-third (60 of 168) of the remaining new articles cited the 2004 report or its derived articles. Twenty-two articles cited the report in more than one context. Most commonly, articles cited the report to support the problem statement in the article, to illustrate the state of the science, or to place the findings in context (Table 5).

Table 5 Citations from the updated health literacy report: Reasons for citing the 2004 AHRQ report

Reason for citation | Number of articles citing the report
Citation supports problem statement | 22
Citation illustrates state of the science | 19
Citation places findings in context | 19
Citation shows how study fills gaps | 13
Citation helps to justify use of measure | 8
Citation supports research recommendations of the study | 3
Citation shapes hypotheses | 1
Total number of articles citing the report or derived articles | 60^*^

* 22 articles cite the report more than once, so total reasons for citing the AHRQ report exceed the number of articles.

The most commonly cited reference was the DeWalt et al. article.23 Our analysis of published literature from ISI Web of Science and PubMed Central also supports the finding that the DeWalt article was the most heavily cited source (Figure 3). The weight of the citation is reflected in the arrow.

Figure 3 Weight and interconnectedness of health literacy citations to the AHRQ report and derived articles*

Figure 3 illustrates the weight and interconnectedness of health literacy citations to the AHRQ report and derived articles. Specifically, it illustrates forward tracing for the following citations: Berkman et al., 2004,9 DeWalt et al., 2004,23 and Pignone et al., 2005.24 The original report (Berkman et al., 20049) resulted in two journal articles. Together, the journal articles were cited more often (181 articles cited DeWalt et al., 200423, Pignone et al., 200524, or both) than the report (38 articles cited Berkman et al., 20049 only).

Media coverage. The EPC’s literacy and health report generated some media interest. EPC investigators, along with authors of a report from a committee of the Institute of Medicine (IOM) on health literacy (Health Literacy: A Prescription to End Confusion), presented their findings to the National Press Club in Washington, D.C., on April 8, 2004. Carolyn Clancy, the AHRQ Director, introduced the reports. However, beyond the Press Club appearance, key informants familiar with the EPC report’s release did not remember significant media coverage. One key informant noted that even the Press Club publicity was somewhat stifled by testimony given by the then-Secretary of State Condoleezza Rice before the U.S. Congress that same day. One stakeholder remembered that the AMA (the report’s sponsor) used its newsletters, weekly newspaper, and Website to disseminate results.

Dissemination through downloads and requests for the AHRQ report. AHRQ maintains a record of downloads through HTML and PDF formats since the publication of the report. Over time, interest in the executive summary in both PDF and HTML formats continues to be quite high (Figure 4) (2004 through October 2010). The only product for which demand has declined over time is the PDF format of the full report. AHRQ’s Clearinghouse processed 613 orders for a total of 1,196 copies through the same period.

Figure 4 Web-based metrics: Literacy and health outcomes

Notes: Visits: a series of actions that begins when a visitor views the first page from the server and ends when the visitor leaves the site; these are a good indication of traffic to a site in terms of users. Page views: access to any file classified as an HTML page. The page and its embedded files count as a single page view; these are a good indication of usage of content. Download: access to any file type that is not an HTML page, such as PDF, PowerPoint, and multimedia files; these are a good indication of commitment to those file types for use.

Figure 4 illustrates Web-based metrics for downloads and visits of the full report and executive summary of the Literacy and Health Outcomes report in HTML and PDF formats. From 2005–2006 through FY 2009–2010, visits and views of the executive summary in HTML format have stayed relatively high (12,000–15,000 14,000 per year). Downloads of the full report in PDF format peaked at over 13,000 in FY 2005–2006, but have since fallen to about 6,000 in FY 2009–2010. All other product use (visits and views of the full report in PDF or HTML format, visits and downloads of the executive summary in PDF format) has been relatively stable over the same period, ranging roughly between 3,500 to 5,500 visits, views, or downloads per year.

Collaboration. EPC investigators were able, despite some constraints, to collaborate to fill research gaps following publication of the report. Some key informants believed that the EPC investigators were not funded either to disseminate the reports more broadly or to maintain systematic contact with policymakers or key stakeholders; this problem made it difficult for them to build on report findings.

However, several of the EPC investigators were in a position, as a result of their prominence in the field independent of the report, to collaborate on future health literacy research. Both Drs. DeWalt and Pignone were involved with health literacy before the EPC report and continued their work in the field after completion of the report. Their participation in the EPC report, while only one of many qualifications, did prove helpful in procuring future work. For example, AHRQ awarded a team led by Dr. DeWalt with a project to develop a Universal Precautions Care Toolkit. One respondent noted that although Dr. DeWalt’s clinical research may have been a more crucial factor in the AHRQ decision, participation with writing the EPC report was also likely to have been influential.

The EPC report, along with several other seminal developments such as the IOM report, ushered in new interest in health literacy that opened pathways for consultation and collaboration. “[T]he report helped to create a climate that created interest in the area [of health literacy].” One key informant noted that “the 2004 report helped on some level to push things in this direction so that AHRQ starts funding things like this [AHRQ-funded Universal Precautions] toolkit.”

One key informant noted that the topic of health literacy had been present for some time (it was a part of Healthy People 2010), but that the EPC report (together with the IOM report) pushed the topic to new visibility. The AHRQ and IOM reports led to reassessments of the topic; for example, two internal meetings with AHRQ leadership in 2005 changed the course of AHRQ involvement in health literacy. The EPC and the IOM reports helped convince the AHRQ leadership of the need to create an action plan for moving forward with research on the issue.

The ascendency of health literacy as a topic also resulted in more and bigger health literacy conferences. For example, the AHRQ Health Literacy Annual Research Conference has been established and has built interest in the field. The gaps in evidence highlighted by the EPC report illustrated that the field of research was “not going to take care of itself without some nurturing.” One key informant from AHRQ noted the direct correlation between the report and the conference:

“[The conference] is very much trying to build the field, [to recruit] a cadre of researchers capable and interested in health literacy. One of the findings of the report was that there is not enough research to form an evidence base, and one of the ways to get more research is to support the development of young researchers who go into this area.”

Short-term impact: Influence on funding priorities. Of the 92 Requests for Applications (RFAs) and Program Announcements (PAs) identified through our searches, 17 (funded by a variety of agencies within NIH and AHRQ) preceded the release of the report. This tally suggests that the funders were pursuing active support of this field even before the release of the systematic review. Of the remaining 75 RFAs and PAs, four cite the AHRQ report.

According to key informants, the release of a NIH PA titled Understanding and Promoting Health Literacy (RO1 and RO3) in 2004 was a major development for the field of health literacy. The announcement, made jointly by NIH and AHRQ, has been reissued: the R03 mechanism in 2004, 2006, and 2010 and the R01 in 2010. An R21 mechanism was first issued in 2006 and reissued in 2010. Of the total of eight such PAs, the first four do not cite the EPC’s report on literacy and outcomes. The lack of citation to the EPC report is not compelling evidence of lack of impact: one funder noted that “the report influenced my thinking when it came out but that was 6 years ago. I didn’t specifically pull it off the shelf [when commissioning new work] and look at it because it had already become part of the way I think.” The remaining four PAs cite both the EPC report and the IOM report.

According to our key informants, the PA is important to health literacy researchers because it lets them know that “there is a place that they can apply for research funding.” One key informant noted that, along with the IOM report, the EPC report provided a foundation on which a PA and subsequent funding could be based.

Another key informant suggested that the EPC report was important for AHRQ internally. In this view, without the strong evidence base provided by the report, it would be hard for AHRQ to make the case that health literacy was an area that deserved research funding.

Although key informants believed that the EPC report had a role in increasing funding for health literacy, generally they were unable to identify many specific requests for funding or funding prioritization documents that referred to the report. They provided several explanations for this situation.

First, report findings were not compatible with future research. “The findings from the first 2004 AHRQ report said [that] there is not a lot of evidence to know what to do, so it was a null finding. It is hard to know what to do with a null finding.”

Second, the very nature of the topic is difficult to translate into funded research. Health literacy is relevant across the entire health care continuum, but it is not specific to any particular clinical area. Several key informants stated that funding and interest tend to cluster around diseases; researchers or research funders taking this traditional approach may be not be able to connect the importance of health literacy to their field of study. Projects tailored to specific topic areas defined by condition (e.g., diabetes or HIV/AIDS) might be needed to capture interest and funding from outside the health literacy community.

Third, dissemination could have been planned better and targeted to end users. Much of the dissemination occurred through the leadership of the content experts on the project rather than through a planned formal process. Respondents noted citing the report routinely in the numerous presentations that they make on health literacy.

Finally, the report itself could have been easier to use. One key informant described it as long and difficult to digest completely. Another suggested that the future research needs section could have been clearer and more thoughtfully produced.

Short-term impact: Influence on policy or practice guidelines. Some organizations have developed policies about health literacy since 2004, but key informants noted the difficulty of directly attributing those developments to the EPC report. Key informants noted that the report’s failure to change policy and practice guidelines in any substantial way may be more the result of the state of research and literature on health literacy than the shortcoming of the report. At the time of the 2004 report on literacy and health outcomes, the field was still in nascent stages of development; the report made it clear that “there was not enough clear data in any one field to make a guideline about anything.” This finding made it impossible for policy or guideline developers to distill definitive principles related to health literacy.

Although we did not identify any direct changes in policy or practice guidelines as a result of the report, key informants thought that the EPC report, in conjunction with simultaneous developments in the field, has pushed health literacy research to a level at which policy or practice guidelines are inevitable. One key informant said that organizations like the AMA, the American College of Physicians, and the Joint Commission have all taken note of developments in health literacy and are likely to institute guidelines once the evidence base proves sufficient.

Medium-term impact: Knowledge generation. Key informants repeatedly referred to the AHRQ EPC report as a foundational document. They mentioned that it is frequently referenced (the report and its subsequent articles) in health-literacy-related, peer-reviewed articles. Several key informants referred to it as a “basic citation,” used to demonstrate that health literacy is a problem that needs to be addressed. As noted earlier, our analysis of the health literacy update articles supports the notion that the 2004 report is cited primarily as a means of establishing the extent and nature of the problem.

In addition, 13 of 60 citations referred to the 2004 report as means of illustrating that their research addressed a gap identified by the report. An additional three studies referred to the AHRQ report and its products to support their own conclusions for future research.

In addition to the impact on other investigators, the report had an impact on the future research of the EPC investigators who wrote it. Independent of the EPC report, the EPC content experts were pursuing research in health literacy. However, their involvement in the report had two impacts. First, it helped to clarify for them the status of health literacy research and the gaps that needed to be filled. Second, it was one of many reports that provided them with a strong reputation for health literacy research. They were able to parlay their experience into future work and prominence in the field: serving on review panels, writing editorials, and presenting and planning major conferences. Without writing the report, that prominence and influence may have taken longer to achieve; “there is no doubt that had we not done that [EPC Health Literacy] report, in my mind, there is no way that we would have gotten the prominence that we did so early.” The fact that they were a part of the review helps to keep the document alive through their experiences and visibility throughout the health literacy community; for example, one of the key informants is often asked to give presentations on health literacy at conferences and usually includes a slide on the evidence review as background.

Although the report did influence future research, several key informants judged that the report could have done a better job of reaching important audiences. One key informant commented that the report dissemination was overly focused on clinical researchers already in the field rather than methodologists. These researchers may be more interested in clinical interventions than activities such as scale development, which has not been sufficiently pursued even though the 2004 report identified this work as an important gap. This key informant suggested that the report should be presented to different audiences, for example methodologists, that may not have thought of health literacy as an area for research but that may include individuals who may be more qualified or interested in filling some of the methodological research gaps. Another key informant was concerned that the report could have been more widely cited and utilized in subsequent research but offered a different explanation: namely, perhaps the report was not used as much as it could have been because the people who wrote it were not sufficiently steeped in health literacy research and the front lines of health literacy work.

Long-term impact: Changes in clinical or patient practice. In general, key informants felt that the report’s impact on clinical and patient practice was tangential at best. The report “helped to coalesce the field and bring things together” and “create a climate that created interest in the area,” but most key informants saw the report as several steps removed from changes at the clinical or patient practice level. Some of the reasons that the report has not changed clinical or patient practice can be attributed to the report itself. Several key informants noted that the report was not written for clinicians; the comprehensive review of literature is helpful for researchers but unwieldy for clinicians. One key informant suggested the creation of complementary documents created specifically with clinicians in mind. Another noted that the report does not work back from what needs to be done at the level of the clinician; as a result, the analysis and gaps feel disconnected from health literacy in the practical context.

One key informant discussed the strides made by AMA in training physicians and other health professionals on health literacy topics with a “Train-the-Trainer” program. This person mentioned that the videotapes and training materials had reached thousands of physicians and other interested parties. Initial feedback indicated the trained individuals had at least partially incorporated some methods to improve their patient communication skills. The EPC report was not the inciting factor behind the training, but the AMA was well aware of the report’s conclusions when they set out to create the training. Another key informant noted that important organizations are starting to incorporate health literacy into their work; the respondent thought that some credit can be given to the report for advancing the field far enough to get these kind of results in a short period of time: “Big institutions like IHI[Institute for Healthcare Improvement] are starting to integrate health literacy. Whether they were influenced by the 2004 report is a stretch, but a lot of this might have moved faster because of the report.”

In short, respondents felt that the EPC report, along with other developments in the field, created the environment in which the AMA, IHI, and other influential organizations are putting resources into health literacy improvements.

Long-term impact: Changes in health outcomes. The key informants generally agreed that if the report had any effect on health outcomes it was indirect, for many of the same reasons already discussed. They noted that the report is meant for researchers and that the bulk and content of the report make it hard to read; “these reports do not support adoption and spread; they are hard to get the gist of.” One key informant suggested that it takes significant amounts of time to translate research into health outcomes and concluded that sufficient time had not passed to judge the 2004 report.

### Impact of EPC Reports (KQ 1): The Omega-3 and Cardiovascular Disease Case Study

Inputs. The omega -3 reports on CVD were part of a series of reports requested and funded by the Office of Dietary Supplements(ODS), National Institutes of Health. The first authors of the three-part series on CVD were Ethan Balk, M.D., M.P.H., (CVD),13 Chenchen Wang, M.D., M.Sc. (CVD risk factors),10 and Harmon Jordan, Sc.D., (animal and other studies).12 As noted earlier, this methods project used the two reports focusing on outcomes in humans, with the exception of one indicator for short-term impact (citation of the report or articles) and for medium-term impact (knowledge generation). For these two indicators, we derive information from an ongoing update of the literature by Balk and colleagues for the Balk et al. 2004 report. No similar resource was available for the Wang et al. report; conducting an update of the literature for the Wang et al. report would have been outside the scope of this methods project.

Outputs. In March 2004, AHRQ released both omega-3 reports on CVD and on CVD risk factors. The CVD risk factors report resulted in two journal articles, for which Dr. Balk was the first author.27,28 Dr. Balk also published a methods paper on systematic reviews of nutrition topics based on several omega-3 reports.29 The CVD report prompted a journal article for which Dr. Wang was the first author.30 After the release of the EPC reports, the ODS(the report funder) and the National Heart, Lung, and Blood Institute (NHLBI) organized two workshops to discuss priorities for future funding.

Short-term impact: Increased awareness of issues. Our analysis of the short-term impact of both reports, unless otherwise stated, comes from several sources: evidence of citation of the report through searches from the updated report (for Balk et al. alone), ISI Web of Science, and PubMed Central; dissemination through downloads and orders of the AHRQ report; qualitative reports of media interest; and heightened collaboration in the field.

Citation of the report. Our analysis of the literature from the omega-3 update search suggests some citation of the 2004 report (Appendix D). Seventeen of 66 articles identified in the update search were published before the release of the report and/or articles and could not, therefore, have been influenced by the report. Of the remaining 49 articles, seven cite the omega-3 report or subsequent journal articles (Table 6). Most articles cite the report and articles to place their findings in context or to establish the state of the science. This finding is echoed in key informant interviews: one stakeholder noted her perception that the report was cited in the body of evidence primarily as a supporting document.

Table 6 Citations from the updated omega-3 and cardiovascular risk factors and intermediate markers report: Reasons for citing the 2004 AHRQ report

Reason for citation | Number of articles citing the report
Citation places findings in context | 4
Citation shows how study fills gaps | 2
Citation illustrates state of the science | 1
Total number of articles citing the report or derived articles | 7

Figure 5 illustrates the weight and interconnectedness of the 336 citations from the two 2004 omega-3 reports that cited a single AHRQ report or journal article (an additional 34 articles cited more than one AHRQ report and/or journal article). The reports resulted in three journal articles that summarized the reports and one that addressed broader concerns about systematically reviewing the literature in nutrition. Two of the journal articles were heavily cited (Figure 5).

Figure 5 Weight and interconnectedness of omega-3 citations to the AHRQ report and derived articles*

*This figure illustrates forward tracing for the following citations: Wang et al., 2004,^10^ Balk et al., 2004,^11^ Wang et al., 2006,^31^ Balk et al., 2006,^27^ Balk et al., 2006,^28^ and Balk et al., 2007.^29^

Figure 5 illustrates the weight and interconnectedness of omega-3 citations to the AHRQ report and derived articles. Specifically, it illustrates forward tracing for the following citations: Wang et al., 2004,10 Balk et al., 2004,11 Wang et al., 2006,31 Balk et al., 2006,27 Balk et al., 2006,28 and Balk et al., 2007.29 The two reports (Wang et al., 200410 and Balk et al., 200411 ) resulted in four journal articles (Wang et al., 2006,31 Balk et al., 2006,27 Balk et al., 2006,28 and Balk et al., 200729). The journal articles were cited more frequently (195 articles cited Wang et al., 200631 only and 88 articles cited Balk et al., 200628 only) than the reports alone (10 articles cited Balk et al., 200411 only and 14 articles cited Wang et al., 200410 only).

Media coverage. AHRQ and ODS orchestrated the press release, and it received some media publicity. Several key informants noted coverage from popular media as well as scientific media. Key informants also noted that omega-3 fatty acids have received substantial coverage overall on their positive effects.

Dissemination through downloads and orders of the AHRQ report. AHRQ’s record of downloads through HTML and PDF formats since the publication of the reports through October 2010 show a peak of interest in the year following the report (downloads of the full report); interest leveled off after that point (Figures 6 and 7). For both reports, the executive summary remains the most consistently sought-after product (visits and views in the HTML format). AHRQ’s clearinghouse processed 103 orders for a total of 132 copies of the Balk et al. CVD report and 123 orders for a total of 175 copies of the Wang et al. risk factor report.

Figure 6 Web-based metrics: Effects of omega-3 fatty acids on cardiovascular disease

Notes: Visits: a series of actions that begins when a visitor views the first page from the server and ends when the visitor leaves the site; these are a good indication of traffic to a site in terms of users. Page views: access to any file classified as an HTML page. The page and its embedded files count as a single page view; these are a good indication of usage of content. Download: access to any file type that is not an HTML page, such as PDF, PowerPoint, and multimedia files; these are a good indication of commitment to those file types for use.

Figure 6 illustrates Web-based metrics for downloads and visits of the full report and executive summary of the Effects of Omega-3 Fatty Acids on Cardiovascular Disease report in HTML and PDF formats. From FY 2004–2005 through FY 2009–2010, visits and views of the executive summary in HTML format have gradually declined over time. Visits to the executive summary declined from approximately 10,000 to approximately 8,000. Views of the executive summary declined from approximately 11,000 to approximately 8,400. Downloads of the full report in PDF format peaked at over 14,500 in FY 2005–2006, but have since fallen to about 2,500 in FY 2009–2010. Visits and views of the full report in HTML format have also gradually reduced over time with the exception of a secondary peak in FY 2008–2009. All other product use (visits to the full report in PDF format, visits and downloads of the executive summary in PDF format) has been relatively stable over the same period, ranging roughly between 1,400 to 3,400 visits or views per year.

Figure 7 Web-based metrics: Effects of omega-3 fatty acids on cardiovascular risk factors and intermediate markers of cardiovascular disease

Notes: Visits: a series of actions that begins when a visitor views the first page from the server and ends when the visitor leaves the site; these are a good indication of traffic to a site in terms of users. Page views: access to any file classified as an HTML page. The page and its embedded files count as a single page view; these are a good indication of usage of content. Download: access to any file type that is not an HTML page, such as PDF, PowerPoint, and multimedia files; these are a good indication of commitment to those file types for use.

Figure 7 illustrates Web-based metrics for downloads and visits of the full report and executive summary of the Effects of Omega-3 Fatty Acids on Cardiovascular Risk and Intermediate Markers of Cardiovascular Disease report in HTML and PDF formats. From FY 2005–2006 through FY 2009–2010, visits and views of the executive summary in HTML format have gradually declined over time. Visits to the executive summary have declined from approximately 11,000 to about 7,000. Visits to the executive summary have declined from over 8,500 to over 5,500. Visits and views of the full report in HTML format have also gradually reduced over time with a secondary peak in FY 2008–2009. All other product use (visits and downloads of the full report in PDF format, visits and downloads of the executive summary in PDF format) has been relatively stable over the same period, ranging roughly between 1,000 to 4,000 visits or views per year.

Collaboration. The co-investigators on this topic who were content experts had substantial expertise before their involvement in the report; thus, the report did not serve as a mechanism to create opportunities for collaboration with their peers on the topic. Nonetheless, participation did play a valuable role. As one key informant noted, “Was the report the single most important factor [in helping to obtain additional funding]? No, but it was a contributing factor that helped us figure out what our research questions would be. Maybe it didn’t stimulate an initial collaboration, but it certainly contributed in a lot of different ways.”

Co-investigators who were methodologists (i.e., EPC investigators) did not pursue additional work in this content area, so they did not seek opportunities for collaboration on this specific topic. They did, however, make connections with nutrition experts at Tufts as a result of this work and so expanded their capacity to do nutrition-related reviews.

Short-term impact: Influence on funding priorities. We found 9 RFAs and 25 PAs that cited the term “omega-3,” “fish oil,” “n-3 fatty acids,” or “omega-3 fatty acids.” Four RFAs and two PAs preceded the release of the report. None cited the EPC reports or articles. The low yield of RFAs and PAs was validated by key informants who cited the importance of investigator-initiated research in this field.

As for influence of the report on funding solicitations, as noted earlier, NHLBI and ODS collaborated on two workshops. NHLBI’s first workshop proposed a large clinical trial, but the lack of funding support prevented further evolution of the proposal. The second workshop resulted in a peer-reviewed journal article that was cited by three articles in the update search for the Balk et al. 2004 report and was reported by key informants to be influential in investigator-initiated funding ideas. Our review of citations using ISI Web of Science and PubMed Central found that 39 studies cited the article from the NHLBI workshop.32 In addition, the workshop served as means of convening experts in the field, who then went on to submit investigator-initiated awards. As one key informant noted, “Many of the successful applicants are in fact individuals who participated in our workgroups. Once they understood and recognized that it was unlikely for dollars to be set aside to support a specific funding opportunity in this area they submitted their applications and thoughts as an investigator-initiated application.”

ODS recently conducted an assessment of the effect of EPC omega-3 reports on their grant portfolio and found that only one of 20 grants cited the AHRQ report. One possible reason for the citation could be that the sole investigator who cited the AHRQ report was involved in the workshop and knew about the reports beforehand.

Key informants noted that the reports lacked specificity, particularly when compared to other reports (e.g., from the IOM) that separate “major” knowledge gaps from noncritical research gaps. One key informant suggested that the lack of specificity was “probably reflective of the panel makeup-maybe some of the AHRQ reports did not have the quorum of nutrition scientists that they needed to phrase the research questions.”

Short-term impact: Influence on policy or practice guidelines. Key informants generally did not believe that the EPC reports had impact on policy and practice guidelines for several reasons. First, the AHA guidelines on eating oily fish preceded the reports; the AHA did not change their guidelines based on the reports. Second, no translation of the AHRQ report to clinical recommendations exists. A third explanation is that the evidence base is not compelling to guideline developers. Finally, one key informant noted that guideline developers may not always be driven by evidence.

When systematic reviews follow the publication of guidelines (e.g., the Food and Drug Administration’s decision letter on the qualified health claim for food labeling on omega-3 fatty acids and cardiovascular health)33 and do not contradict them, the reviews have only a limited scope for influencing later iterations of these practice guidelines.

Medium-term impact: Knowledge generation. Two sets of authors cited one of the AHRQ report13 and two journal articles28,30 to illustrate how their studies filled gaps identified by the AHRQ review.

Investigators on the EPC team expanded their portfolio of research in the area of systematic reviews of nutrition topics. Content experts became more involved in systematic review work and related activities, serving on a Technical Expert Panel and on guideline committees. Additionally, the methodological challenges of conducting systematic reviews in the nutrition field spurred the Tufts team to seek additional funding on methods from NIH.

External constraints include funding, the state of current patient practice, and the existing knowledge base among funders and reviewers. Regarding funding, one key informant noted that some of the omega-3 gaps require studies that may be long-term and expensive and, therefore, be less likely to be funded. The high prevalence of omega-3 supplementation was cited as a constraint; the implication of such high prevalence is that studies may have trouble recruiting new users to meet their sample size. One key informant believed that EPC reports were unlikely to have attributable impact because of the existing knowledge base among funders and investigators. “It’s hard to imagine that the gaps identified in that paper would not already be apparent to another investigator in this field. They already know it’s a gap without reading the AHRQ report.”

Long-term impact: Changes clinical or patient practice. Key informants noted a substantial change in clinical practice and cited the commonplace use of omega-3 supplements. They noted however, that this change is attributable not to single report, but to a body of evidence, with a slow accumulation of data on benefits from 1985 onward (when the New England Journal of Medicine published three studies on omega-3) and limited evidence of harms. “More and more people are getting the message that it’s good for you. Medical advertisers get out there and promote it. Obviously the EPC [report] was just one wave in the ocean.”

Long-term impact: Changes in health outcomes. Key informants uniformly agreed that they could not make a judgment on whether the EPC report has had an impact on health outcomes. They cited the difficulty of attribution of effect to the EPC report in particular.

### Factors Influencing the Impact of EPC Reports (KQ 2)

Key informants discussed a number of benefits that resulted from the EPC reports. Among these were steps such as providing a foundation for the research community to build on, heightening awareness of the gaps in knowledge, increasing the quality of research, and sparking new directions of research. However, the degree to which these reports were influential and well received hinged on several factors including marketing efforts, the very nature of the reports, and factors external to the EPC domain. The following comments, which identify several barriers to effectiveness and offer recommendations for overcoming those problems, are drawn from both sets of key informants (i.e., on the literacy report and the omega-3 reports) unless otherwise noted.

Dissemination. First, dissemination (or lack thereof) was an important barrier and facilitator to the impact of these reports. Many key informants commented that the reports were not well known in the field because of lack of dissemination of the findings and little name recognition for AHRQ. They felt that more effort should be paid to dissemination activities. Simply posting the report to a Website or relying on word of mouth was deemed inadequate. As one key informant noted: “…if we don’t engage in promotional activity it’ll just be one more government report on a shelf.” Improving dissemination in multiple venues and media. Our respondents suggested several improvements for dissemination of such reports in the future. One key informant drew on her experience in a different context and suggested a variety of dissemination activities for future reports, such as presenting them at conferences, conducting webinars, and posting them to social networking sites such as Twitter. Another key informant suggested that authors should publish targeted findings in peer-reviewed journals, thereby increasing exposure of the work to researchers using traditional routes of literature searches.

Identifying “champions.” Other key informants suggested that, for work of this sort, a champion was needed to spur interest among the research community and to promote a collaborative environment in which funders and researchers could align their interests. A champion could help to ensure that such reports were disseminated in appropriate forms to appeal to the intended audiences. Champions could be AHRQ staff, the staff of other agencies nominating or sponsoring the work, report authors, or other stakeholders interested in furthering the field.

Presence of a committed partner. A related issue to having a champion is the presence of a committed partner. One key informant cited the “model” partnership between ODS and AHRQ, where ODS served a critical role before and after the project by being able to identify areas that need to be informed by evidence.

Nature of the reviews and target audiences. A second set of barriers and facilitators to effective use of these reports was related to the nature of the reports themselves. Two authors commented that the reports were dense and were not easy to read, but they were challenged as to how to make the findings more accessible to the intended audience.

“You try hard to make it user-friendly, but it is still a very large report. How do you get through that lengthy report? Who gets through it? How do you make it something that people can use?”

One key informant viewed “the papers published in peer-reviewed journals [as] most helpful. Perhaps because peer-reviewed publications are much more targeted which makes it easier, plus people are more used to citing and going to those kinds of sources.”

The reports were also viewed as catering to a narrow audience of researchers. They were not seen as suitable for practitioners because they lacked specific guidelines that clinicians could put into practice and because practitioners do not have the time to wade through a thick report to find the relevance for how they could improve their programs. None of the three reports was written for or aimed at patient or advocacy groups.

Expanding the intended reach of reports. Broadening the targeted audience to include consumers and practitioners would increase awareness and promote change. One key informant highlighted this point as follows: “…marketing to a patient audience might be as effective as anything—then have the patients advocate for change.”

However, to be effective with a broader set of audiences, the reports would need to be sensitive to the needs of different types of readers. One key informant suggested that separate reports could be developed for each intended audience to better address their particular needs and interests. Marketing shorter, action-oriented digests of information to consumers and practitioners would be better received while more detailed reports focusing on gaps in the literature and methods could be developed for researchers and practitioners to help them best use the findings. Another key informant suggested that because the field of health literacy cuts across a wide range of topic areas, the findings of that review could be generalized to appeal to a wider audience.

Improving recommendations. How recommendations were presented was also criticized. Key informants thought that they were too broad, or unclear, or not feasible to implement (or some combination of these problems). One key informant suggested that the report team making the recommendations lacked the knowledge and experience in the subject area needed to understand what it takes to parlay the recommendations into research.

To address these report critiques, suggestions to strengthen the usefulness of the recommendations included the following:

- Seek input from key stakeholders to identify research gaps and develop recommendations: “We could have been clearer in describing the research needs… seeking more feedback would have led to a stronger section.”
- Clearly state the direction that the research should take to fill major gaps in knowledge and advance the field: “More direction on how urgent some of the recommendations may be. Something that indicates urgency. There might be low hanging fruit that people can get a hold of, but if it is not going to fill in major gaps, the field is just going to inch along.”
- Clearly articulate the recommendations and be specific with regard to the type of research needed.

Building on strengths of the systematic review approach. Despite the critiques cited above, key informants mentioned that the methodology the EPC teams used gave credence to their findings. One stakeholder noted that the involvement of methodologists with no preconceived ideas or biases helped to generate a high regard for the reports: they were considered high quality and very accurate. These views suggest that EPCs should build on the core methods used to produce such reports, while collaborating with AHRQ and other stakeholders (e.g., nominators of topics; other agency sponsors) to improve dissemination, readability, and similar aspects of the broader EPC agenda.

External factors. The third set of barriers and facilitators was related to factors external to AHRQ and the nature of the reports; they are less “actionable” to address within AHRQ’s sphere of influence. Several key informants tied to the 2004 report on literacy and health outcomes discussed barriers inherent to a relatively new field of study that have hindered the usability of the report.

Lack of evidence supporting a clear direction for future research. Two key informants noted that the lack of available evidence in favor of a clear direction for future research in the 2004 report was problematic. Study design flaws and small sample sizes prevented the authors from specifying meaningful recommendations about research. Moreover, interventions that were known to have design flaws continued to be funded in subsequent studies because of mandates or “they already had things in the works.”

Lack of research in basic science. Key informants representing both the health literacy and omega-3 reports discussed the lack of basic science to support the growth of each field. As one key informant noted,

“ the challenge has been to get down to the basic science of health literacy. I think the issue is conceptual; people really don’t know what health literacy is. The literature and our writing about it has not been clear enough on what we are measuring in terms of exposure.”

Similarly, another key informant noted the lack of external support from funding agencies to conduct the necessary research.

“Some more basic science that needs to be done [on nutrients and supplements] is not as highly sought as hypothesis-driven research, new and novel idea research.”

Size of the field. Another key informant commented that because of the newness of the field, a relatively small cadre of researchers has been involved in health literacy. Thus, awareness of health literacy as an evolving field is generally lacking among individuals, communities, researchers, and practitioners. Conversely, the literature about the benefits of omega-3 fatty acids (and supplements) has become commonplace; in fact, it might be said to have led to difficulties because more individuals are taking these supplements, thereby complicating potential study designs and creating an obstacle to future research.

Lack of funding. Another external barrier that can affect future research is simply the lack of funding. One key informant (in discussing omega-3 supplements and CVD or risk factors) discussed the difficulty of getting research funded for which “there is really no hypotheses that would support the belief that these agents are anti-arrhythmic.” Moreover, the expense and time needed to conduct needed animal studies can be prohibitive and they are less likely to be funded.

Convergence of findings. Another key informant highlighted the need for researchers to pay more attention to findings and recommendations when data that speak to the same topic do converge, as was the case with the 2004 report on literacy and health outcomes and the IOM report. This observation suggests that timing of the release of report findings could be a factor in how much of an impact the report could have, especially if it follows on the heels of (or immediately precedes) a widely published study or report in the same topic area.