# References

1 Clancy CM, Slutsky JR. (2007). Commentary: a progress report on AHRQ’s Effective Health Care Program. Health Serv Res.
2 Stryer D, Tunis S, Hubbard H, et al. (2000). The outcomes of outcomes and effectiveness research: impacts and lessons from the first decade. Health Serv Res.
3 Atkins D, Fink K, Slutsky J. (2005). Better information for better health care: the Evidence-based Practice Center program and the Agency for Healthcare Research and Quality. Ann Intern Med.
4 Matchar DB, Westermann-Clark EV, McCrory DC, et al. (2005). Dissemination of Evidence-based Practice Center reports. Ann Intern Med.
5 Brown P, Brunnhuber K, Chalkidou K, et al. (2006). How to formulate research recommendations. BMJ.
6 Frank C, Battista R, Butler L, et al. (2009). Making an impact: A preferred framework and indicators to measure returns on investment in health research.
7 W. K. Kellogg Foundation. (2004). Using logic models to bring together planning, evaluation and action: logic model development guide.
8 Taylor-Powell E, Henert E. Developing a logic model: teaching and training guide.
9 Berkman ND, DeWalt DA, Pignone MP, et al. (2004). Literacy and health outcomes, Evidence Report/Technology Assessment No. 87.
10 Wang C, Chung M, Lichtenstein A, et al. (2004). Effects of omega-3 fatty acids on cardiovascular disease, Evidence Report/Technology Assessment No. 94.
11 Balk E, Chung M, Lichtenstein A, et al. (2004). Effects of omega-3 fatty acids on cardiovascular risk factors and intermediate markers of cardiovascular disease, Evidence Report/Technology Assessment No. 93.
12 Jordan H, Matthan N, Chung M, et al. (2004). Effects of Omega-3 Fatty Acids on Arrhythmogenic Mechanisms in Animal and Isolated Organ/Cell Culture Studies, Evidence Report/Technology Assessment No. 92.
13 Balk E, Chung M, Lichtenstein A, et al. (2004). Effects of omega-3 fatty acids on cardiovascular risk factors and intermediate markers of cardiovascular disease, Evidence Report/Technology Assessment No 93.
14 Wang C, Chung M, Lichtenstein A, et al. (2004). Effects of omega-3 fatty acids on cardiovascular disease, Evidence Report/Technology Assessment No 94.
15 Frank C, Nason E. (2009). Health research: measuring the social, health and economic benefits. CMAJ.
16 Wooding S, Nason E, Klautzer, et al. (2007). Policy and practice impacts of research funded by the Economic and Social Research Council. A case study of the future of work programme, approach and analysis: RAND EUROPE, Prepared for the Economic and Social Research Council.
17 Raftery J, Hanney S, Green C, et al. (2009). Assessing the impact of England’s National Health Service R&D Health Technology Assessment program using the "payback" approach. Int J Technol Assess Health Care.
18 Comroe JH, Dripps RD. (1976). Scientific basis for the support of biomedical science. Science.
19 Wooding S, Hanney S, Buxton M, et al. (2004). The returns from arthritis research, Volume 1: Approach, analysis, and recommendations.
20 Hanney S, Buxton M, Green C, et al. (2007). An assessment of the impact of the NHS health technology assessment programme. Health Technology Assessment.
21 Viswanathan M, Ammerman A, Eng E, et al. (2004). Community-based participatory research: assessing the evidence, Evidence Report/Technology Assessment No 99.
22 Berkman ND, Sheridan SL, Donahue KE, et al. Health Literacy Interventions and Outcomes: An Update of the Literacy and Health Outcomes Systematic Review of the Literature.
23 Dewalt DA, Berkman ND, Sheridan S, et al. (2004). Literacy and health outcomes: a systematic review of the literature. J Gen Intern Med.
24 Pignone M, DeWalt DA, Sheridan S, et al. (2005). Interventions to improve health outcomes for patients with low literacy. A systematic review. J Gen Intern Med.
25 DeWalt DA, Pignone MP. (2005). Reading is fundamental: the relationship between literacy and health. Arch Intern Med.
26 Pignone MP, DeWalt DA. (2006). Literacy and health outcomes: is adherence the missing link?. J Gen Intern Med.
27 Balk EM, Lichtenstein AH, Chung M, et al. (2006). Effects of omega-3 fatty acids on coronary restenosis, intima-media thickness, and exercise tolerance: a systematic review. Atherosclerosis.
28 Balk EM, Lichtenstein AH, Chung M, et al. (2006). Effects of omega-3 fatty acids on serum markers of cardiovascular disease risk: a systematic review. Atherosclerosis.
29 Balk EM, Horsley TA, Newberry SJ, et al. (2007). A collaborative effort to apply the evidence-based review process to the field of nutrition: challenges, benefits, and lessons learned. Am J Clin Nutr.
30 Wang C, Harris WS, Chung M, et al. (2006). n-3 Fatty acids from fish or fish-oil supplements, but not alpha-linolenic acid, benefit cardiovascular disease outcomes in primary- and secondary-prevention studies: a systematic review. Am J Clin Nutr.
31 Wang C, Harris WS, Chung M, et al. (2006). n-3 Fatty acids from fish or fish-oil supplements, but not alpha-linolenic acid, benefit cardiovascular disease outcomes in primary- and secondary-prevention studies: a systematic review. Am J Clin Nutr.
32 London B, Albert C, Anderson ME, et al. (2007). Omega-3 fatty acids and cardiac arrhythmias: prior studies and recommendations for future research: a report from the National Heart, Lung, and Blood Institute and Office Of Dietary Supplements Omega-3 Fatty Acids and their Role in Cardiac Arrhythmogenesis Workshop. Circulation.
33 U.S. Food and Drug Administration. Letter responding to health claim petition dated November 3, 2003 (Martek petition): omega-3 fatty acids and reduced risk of coronary heart disease (Docket No. 2003Q-0401).
34 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 [Draft posted Oct. 2007].
35 Chung M, Balk EM, Brendel M, et al. (2009). Vitamin D and calcium: a systematic review of health outcomes, Evidence Report No. 183.
36 Ip S, Chung M, Raman G, et al. (2007). Breastfeeding and maternal and infant health outcomes in developed countries, Evidence Report/Technology Assessment No, 153.
37 Gartlehner G, Hansen RA, Thieda P, et al. (2007). Comparative effectiveness of second-generation antidepressants in the pharmacologic treatment of adult depression, Comparative Effectiveness Review No. 7.
38 Shekelle PG, Morton SC, Keeler EB. (2006). Costs and benefits of health information technology, Evidence Report/Technology Assessment No 132.
39 Balk E, Chung M, Chew P, et al. (2005). Effects of soy on health outcomes, Evidence Report/Technology Assessment No 126.
40 Viswanathan M, Hartmann K, Palmieri R, et al. (2005). The use of episiotomy in obstetrical care: a systematic review, Evidence Report/Technology Assessment No. 112. AHRQ Publication No. 05-E009-1.
41 Morton SC, Maglione MA, Suttorp M, et al. (2004). Pharmacological and surgical treatment of obesity, Evidence Report/Technology Assessment No 103.
42 Shekelle P, Morton S, Maglione M, et al. (2003). Ephedra and ephedrine for weight loss and athletic performance enhancement: clinical efficacy and side effects, Evidence Report/Technology Assessment No 76.
43 Ip S, Glicken S, Kulig J, et al. (2003). Management of neonatal hyperbilirubinemia, Evidence Report/Technology Assessment No 65.
44 Ellis P, Robineson P, Ciliska D, et al. (2003). Diffusion and dissemination of evidence-based cancer control interventions, Evidence Report/Technology Assessment Number 79.
45 West S, King V, Carey TS, et al. (2002). Systems to rate the strength of scientific evidence, Evidence Report/Technology Assessment No 47.
46 Harris R, Lohr KN. (2002). Screening for prostate cancer: an update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med.
47 U. S. Preventive Services Task Force. (2002). Screening for prostate cancer: recommendations and rationale. Ann Intern Med.
48 Berkman ND, Thorp J, JM, Hartmann KE, et al. (2000). Management of preterm labor, Evidence Report/Technology Assessment No 18.