# Peer Reviewers

Mei Chung, M.P.H.

Tufts Medical Center Evidence-based Practice Center

Boston, MA

Jeanne-Marie Guise, M.D., M.P.H.

Oregon Evidence-based Practice Center

Portland, OR

Joseph Lau, M.D.

Tufts Medical Center Evidence-based Practice Center

Boston, MA

Naomi Aronson, Ph.D.

BC/BS Evidence-based Practice Center, Technology Evaluation Center

Chicago, IL