# Methods

This chapter describes the methodological factors we considered in evaluating the impact of systematic reviews on future research and highlights their implications for the methodological approaches selected.

## Methodological Considerations and Approaches

Methodological concerns in identifying the effects of EPC reviews on research (opportunities, priorities, studies begun, and/or studies completed) include the following:

1. attributing impact to the EPC report itself, given that other factors may influence policy decisions or changes in research directions or opportunities;
2. accounting for the time lag between the report and the change in research funding priorities or actual investigations; and
3. taking into consideration what might have occurred in the absence of the EPC report.6,15

These three issues are interrelated. For example, for EPC reports to have any influence or effect will take time, the duration of which will be variable and somewhat unpredictable. Such impacts will take even more time to detect, but the further in time that they occur from the release of the report, the more difficult it is to attribute effect to the individual report. That is to say, exogenous variables could have influenced the impact.

Another challenge is over-attributing impact to the EPC report because of the multiple pathways through which such outcomes could have occurred. Additionally, trying to attribute credit to a particular report assumes that downstream consumers (funders and investigators) can parse the effect of an individual report on their overall thought processes.6 In fact, one study found that policymakers were more likely to be informed by a body of research rather than a specific finding.16 As a result of these concerns, evaluators focus on contribution, rather than attribution, and they lay out a clear logic model to understand the possible pathways for contribution.6

A time lag that is too long will result in impacts that may have already occurred and are difficult to attribute to the EPC report. With too short a time lag, the effects may simply not have had sufficient time to occur. Evaluators suggest that a time lag of 5 to 10 years following the completion of the research is needed for discernible effects to develop, but they caution that a 2-year time lag may be more appropriate for “hot” topics16 or those in which the policy change is relatively simple.

An experimental design, i.e., a comparison of outcomes with and without the EPC report is, of course, neither plausible nor feasible in this context. At a minimum, addressing the counterfactual question—what if the report had not been published?—requires collection of baseline information and context.6

Two basic approaches can be used to answer questions of research impact: historical tracing or forward tracing.17 With historical tracing (as with the classic Comroe and Dripps study 18), evaluators first identify key advances and then determine the bodies of evidence that influenced the key advances. This particular approach relies heavily on bibliometric techniques (e.g., weight and interconnectedness of citations). Forward tracing starts with specific research and can use a variety of methods such as case studies, interviews, questionnaires, and bibliometric techniques to identify both the effects and the pathways for those effects. The former technique requires a comprehensive bibliographic source, without which results are likely to be biased. The latter technique, through its narrower focus on the specific report for which effects are to be determined, uses a more targeted bibliographic search than historical tracing but may be particularly susceptible to biases relating to attribution. An additional concern with case study analyses that are often used in forward tracing is that of selection bias in identifying the cases, which may lead to focusing excessively on positive rather than negative findings or conclusions.

### Implications of Methodological Constraints on Project Methods

We attempted to answer the two key questions using forward tracing for two case studies. We used a combination of methods: key informant interviews, web searches, and bibliometric techniques for citation analysis. These methods are consistent with the most commonly used approach in assessing research impact, the “payback” framework.19,20 The payback framework describes the sequence of activities in the research process, from needs assessment to dissemination, and it identifies a range of benefits or “paybacks” from the research.20

In addressing the two key questions and accounting for potential biases, we took the following tasks to be critical: (1) developing an analytic framework to depict and separate, when possible, the pathways for attribution of impact directly to the systematic review as contrasted with its contribution to a larger set of factors that impact future research; (2) stating the considerations weighed in selecting case studies; and (3) carrying out some assessment of funding priorities before and after the publication of the report to avoid a focus on overly positive findings.

Development and revision of the analytic framework and logic model. Chapter 1 presents our initial analytic framework (Figure 1), which we developed to illustrate the pathways of influence for an individual report. The logic model (Figure 2) represents anticipated outcomes at a broader level, for the AHRQ program. The programmatic considerations illustrated in the logic model are a means of specifying and differentiating among proximal and distal outcomes. In other words, the logic model serves as a heuristic to lay out a temporal sequence for events that lead to impact on future research. The logic model may not always translate directly for specific reports because the implied temporal sequence in it may not always hold true. For instance, “medium-term” impacts on knowledge generation may occur contemporaneously with “long-term” impacts on clinical practice.

The analytic framework, together with the logic model, guided our choice of outcomes, measures, and indicators for impact (Table 1). We explicitly asked each key informant for feedback on the analytic framework and used their input to revise our hypothesized pathways for impact. Their contributions served an important role in clarifying and validating the depicted pathways for impact. In addition, we used other sources to inform the revised version of the analytic frameworks (presented in Chapter 4).

Table 1 Indicators of research outcomes and impact from future research sections in EPC reports

Type of Outcome | Specific Outcome | Indicators | Methods
Short term (1–3 years) | Knowledge generation: heightened awareness of issues and gaps in knowledge | - Heavy citation of the relevant papers or widespread use of a tool arising from the research; - Public interest in the work from media; - Downloaded requests for relevant AHRQ publications; - Requests to EPC investigators to consult with or collaborate with funders, policymakers, or other investigators on research gaps identified by systematic review | - Bibliometric analysis; - Web searches; - Downloaded data (from AHRQ); - Qualitative data from interviews with EPC investigators; - Orders from the AHRQ publication clearinghouse
| Funding priorities included or influenced by systematic review recommendations | - Citation of relevant papers in requests for funding or in funding prioritization documents | - Bibliometric analysis; - Web searches; - Qualitative data from interviews with EPC investigators and funders
| Policy or practice guidelines based on or influenced by results | - Citation of relevant papers in policy or practice guidelines | - Bibliometric analysis; - Web searches; - Qualitative data from interviews with EPC investigators and policy/practice guideline developers
Medium term (4–6 years) | Knowledge generation (filling gaps in the evidence through new studies); - Investigator- initiated research ideas funded; - Responses to requests for proposals | - Citation of relevant papers in successful grant applications | - Bibliometric analysis; - Qualitative data from interviews with EPC investigators and funders
Long term (7–10 years) | Improvement in the quality, safety, efficiency, and effectiveness of health care | - Change in clinical or patient practice; - Change in health outcomes | - Qualitative data from interviews with EPC investigators and AHRQ staff

Selection of case studies. We sought nominations for case studies from EPC directors to identify EPC reports known to have had impact. We identified 16 potential case studies. In evaluating each nomination, we considered and flagged concerns regarding measurement or attribution of impact and the likelihood for potential conflict of interest (Appendix A). In narrowing the selection further from this list, we consulted with senior AHRQ staff, specifically Stephanie Chang and Yen-Pin Chiang.

Two important additional considerations influenced the final selection of the topics: ongoing update activities and variation in the topic. The 2004 report on literacy and health outcomes9 and the 2004 reports on omega-3 and cardiovascular issues10,11 were in the process of updates, either formally or as part of a methods project. In addition, each of these projects represented very different types of topics. Health literacy is a broad topic that influences many different substantive areas; omega-3, by contrast, is a much more focused topic. The variation in topics presented an opportunity to explore different pathways for impact. The choice of these relatively early-generation reports, although suitable for the evaluation of medium- and long-term outcomes, risks the production of insights or conclusions that are no longer relevant in light of changes in the EPC program.

Assessment of funding priorities before and after the systematic reviews. We addressed this issue through reviews of federal requests for applications and program announcements from 1993 to 2010 (a period that includes 11 years of funding before release of the reports and 6 years thereafter). We also asked funders who offered anecdotal evidence of changes in funding priorities to describe the contribution of the AHRQ report to these changes.

### Data Sources for Bibliometric Analysis

Our study, to the best of our knowledge, is the first to examine the impact of systematic reviews on future research. No guidance exists for how to select among sources of data and how to analyze citations. We drew, therefore, on established social-science approaches for program evaluations.

We began our searches by attempting to confirm the feasibility of the historical tracing approach rather than forward tracing. Our searches on health literacy used terms such as “literacy” or “health literacy,” depending on the source; when possible, we used date limits from 2003 to 2010. These searches yielded more than 4,000 hits; we interpreted these results to suggest that a forward-tracing approach would be more feasible than historical tracing.

In the absence of guidance on the best source of data, we planned to test the use of multiple sources of data. Specifically, we conducted searches in multiple funding databases to identify funding publications associated with EPC reports and solicitations that cited the selected EPC reports or associated publications. To identify the most appropriate data sources for citation analysis for the two case studies, we undertook an exploratory search for one specific EPC systematic review (Community-based Participatory Research: Assessing the Evidence)21 that we knew from personal communications with investigators and funders to have had an impact on knowledge generation, i.e., on the development of federal requests for proposals and applications. We conducted an exhaustive search and found that numerous data sources did not yield any results. Appendix B presents the full search results for all data sources.

We used the results of this exploratory work to inform the choice of data sources for this task (Table 2). We describe methods for each source below.

Table 2 Data sources for bibliometric analysis

Type of Literature | Source | Ease of Use^*^ | Import Function | Dates of Coverage
Published literature | ISI Web of Science | Satisfactory | Yes | Science Citation Index Expanded (SCI-EXPANDED)—1955-present Social Sciences Citation Index (SSCI)—1956-present Arts & Humanities Citation Index (A&HCI)—1975-present
| MEDLINE® via PubMed | Satisfactory | Yes | 1950-present
Ongoing studies | ClinicalTrials.gov | Satisfactory | No | Unavailable Updated continuously
| NIH RePORTER (previously CRISP) | Difficult | No | 1986-present
Solicitations | National Institutes of Health [NIH] Guide for Grants and Contracts | Difficult Phrase searching unavailable | No | 1993-present Historical files available 1970–1992

* We rated ease of use as “Satisfactory” or “Difficult.” Sources with a “Satisfactory” rating recognized phrase searching and Boolean connectors, or they provided other helpful search instructions. Sources with a “Difficult” rating did not recognize phrase searching and/or Boolean connectors, and/or they gave no search instructions, and/or the search results did not contain the search terms.

Note: CRISP = Computer Retrieval of Information on Scientific Projects.

Published literature. We used information provided by our key informants to obtain a list of “first-generation” references; those are publications derived directly from the report (i.e., peer-reviewed publications drawing upon the reports) (Table 3). We then used ISI Web of Science and PubMed Central citation listings in MEDLINE for each reference to obtain information on the weight and interconnectedness of citations. We ran searches in these sources for each of the original citations and first-generation citations to obtain the list of “second-generation” citations.

Table 3 AHRQ systematic review and related citations

Systematic Review | Original Citation | First-Generation Citations
Report on literacy and health outcomes | - Berkman ND, DeWalt DA, Pignone MP, Sheridan SL, Lohr KN, Lux L, Sutton SF, Swinson T, Bonito AJ: Literacy and health outcomes, summary, evidence report. Rockville, MD, Agency for Healthcare Research and Quality, 2004 (Tech. Assessment no. 87) | - DeWalt DA, Berkman ND, Sheridan S, Lohr KN & Pignone MP. Literacy and health outcomes: A systematic review of the literature. J Gen Intern Med. 2004;19:1228–1239.; - Pignone M, DeWalt DA, Sheridan S, Berkman N, Lohr KN. Interventions to improve health outcomes for patients with low literacy. A systematic review. J Gen Intern Med. 2005;20:185–92.
Omega-3 reports | - Wang C, Chung M, Lichtenstein A, et al. Effects of omega-3 fatty acids on cardiovascular disease. Evidence Report/Technology Assessment No. 94 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center, under Contract No. 290-02-0022). AHRQ Publication No. 04-E009-2. Rockville, MD: Agency for Healthcare Research and Quality 2004.; - Balk E, Chung M, Lichtenstein A, et al. Effects of omega-3 fatty acids on cardiovascular risk factors and intermediate markers of cardiovascular disease. Evidence Report/Technology Assessment No. 93 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). AHRQ Publication No. 04-E010-2. Rockville, MD: Agency for Healthcare Research and Quality 2004. | - Wang C, Harris WS, Chung M, et al. n-3 Fatty acids from fish or fish-oil supplements, but not alpha-linolenic acid, benefit cardiovascular disease outcomes in primary- and secondary-prevention studies: a systematic review. Am J Clin Nutr. 2006 Jul;84(1):5–17.; - Balk EM, Lichtenstein AH, Chung M, et al. Effects of omega-3 fatty acids on coronary restenosis, intima-media thickness, and exercise tolerance: a systematic review. Atherosclerosis. 2006 Feb;184(2):237–46.; - Balk EM, Lichtenstein AH, Chung M, et al. Effects of omega-3 fatty acids on serum markers of cardiovascular disease risk: a systematic review. Atherosclerosis. 2006 Nov;189(1):19–30.; - Balk EM, Horsley TA, Newberry SJ, et al. A collaborative effort to apply the evidence-based review process to the field of nutrition: challenges, benefits, and lessons learned. Am J Clin Nutr. 2007 Jun;85(6):1448–56.

Ongoing studies. We searched two sources for ongoing studies and found little usable information. NIH RePORTER does not allow downloads of abstracts when searches yield more than 100 abstracts. Abstracts, when downloadable, lack sufficient information to judge whether the AHRQ reports and their derivative products influenced these studies. We do not use these results in the analysis.

Solicitations. We searched the National Institutes of Health [NIH] Guide for Grants and Contracts Website for “health literacy” and “omega 3,” respectively. The Website is limited in its search functionality: if users request inactive solicitations, they cannot set date limits. The yield included 92 requests for applications (RFAs) and program announcements since 1993 for health literacy and 34 for omega-3 (Appendix C).

### Update Searches

As noted earlier, one of the methodological limitations of the forward-tracing approach is its focus on positive results. Searches for studies in ISI Web of Science or MEDLINE^®^ provide information on weight and interconnectedness of citations, but they cannot provide information on the extent to which the systematic review and its byproducts influenced future research. To understand the extent to which systematic reviews have had impact, we needed a denominator, which is effectively the (number of) studies that could potentially have cited the systematic review. As noted earlier, we selected both these case studies because they were being updated at the time (early 2010), and thus we were able to obtain updated search results for both of them.

The health literacy report conducted a full update of the literature and identified 177 new citations from 2003 to 2010 that met inclusion criteria.22 The update search for omega-3 was an abbreviated search for the Balk et al. report on cardiovascular risk factors and intermediate markers and was conducted primarily to understand signals for whether the reports were ready to be updated.13 These searches were conducted only in key journals and yielded 66 new citations that met inclusion criteria.

The availability of the results of these update searches considerably simplified the effort of identifying the denominator. We did not undertake this effort for the Wang et al. report on cardiovascular disease14 because the search for updated literature would have been beyond the scope of this project.

We obtained full-text articles for each citation and reviewed each article for evidence of having cited the systematic review or associated articles (Appendix D). We abstracted data showing how each article cited the systematic review or associated articles. We reviewed each article and abstraction dually and recorded the context and purpose of the citation.

### Selection and Interviews of Key Informants

We planned to conduct key informant interviews with no more than nine EPC investigators and other key informants such as practice guideline developers, funders, other investigators, or AHRQ staff for each of the two selected EPC reports. We used snowball recruitment to identify and recruit key informants. We intended to interview at least two investigators of the original report, two funders, and two external experts. We began our interviews with the investigators of the reports and were guided by their input in the selection of subsequent key informants. A total of six key informants for the literacy and health outcomes case study and seven for the omega-3 and cardiovascular disease case study were able to provide us input within the timeframe of this report (Appendix E).

The chief purposes of the interviews were to locate (1) relevant funding solicitations and investigator-initiated funding and to identify (2) barriers and facilitators to the use of past reports for developing funding agendas or solicitations (Table 4). In addition to the questions listed in Table 4, we requested that the EPC investigators review and add to the list of citations (reports, journal articles, book chapters) that we had identified as being associated with their report. We also requested information on related ancillary materials produced by the EPC or AHRQ such as editorials, op-ed articles, policy briefs, presentations to academic and policy gatherings, continuing medical education materials, and clinical practice guidelines.

Table 4 Questions for key informants

Indicator | Question
Public interest in the work from media | Have you or others on the team been asked to speak with members of the media? [If yes] Can you describe your experience?
Requests to EPC investigators to consult with or collaborate with funders, policymakers, or other investigators on research gaps identified by systematic review | Have you or others on the team been asked to consult with or collaborate with funders on research gaps identified by systematic review? Policymakers? Guideline developers? Other investigators? Other stakeholders? [If yes] What was the nature of the collaboration? What factors contributed to collaboration? What do you perceive as barriers to collaboration? How can these barriers be addressed?
Citation of relevant papers in requests for funding or in funding prioritization documents | To your knowledge, has [the report and/or its ancillary products] influenced requests for funding or in funding prioritization documents? Has [the report and/or ancillary products] been cited in requests for funding or in funding prioritization documents? What factors contributed to its use? [If yes] Can you share these materials? What do you perceive as barriers to the use of the report? How can these barriers be addressed?
Policy or practice guidelines based on or influenced by results | To your knowledge, has [the report and/or its ancillary products] influenced policy or practice guidelines? Has [the report and/or ancillary products] been cited in policy or practice guidelines? [If yes] Can you share these materials?
Citation of relevant papers in successful grant applications | To your knowledge, has [the report and/or its ancillary products] influenced investigator-initiated funding? Has [the report and/or ancillary products] been cited in successful grant applications? What factors contributed to its use? [If yes] Can you share these materials? What do you perceive as barriers to the use of the report? How can these barriers be addressed?
Change in clinical or patient practice | To your knowledge, has [the report and/or its ancillary products] resulted in changes in clinical or patient practice? [If yes] What sources support evidence of such change? What factors contributed to its impact? What do you perceive as barriers to the use of the report? How can these barriers be addressed?
Change in health outcomes | To your knowledge, has [the report and/or its ancillary products] resulted in changes in clinical or patient practice? [If yes] What sources support evidence of such change? What factors contributed to its impact? What do you perceive as barriers to the use of the report? How can these barriers be addressed?

### Analysis of Key Informant Interviews

We used QSR International’s NVivo 9 qualitative data analysis software to analyze the data. The Principal Investigator (PI) conducted all the interviews. Two other investigators generated the transcripts from the interviews, and the PI reviewed all the transcripts for accuracy. One staff member coded all the interviews in NVivo. To do this, he used the analytic framework and logic model as a primary structure for coding the interview questions that related directly to short-, medium-, and long-term impact of the report; he then used the grounded theory approach for open-ended questions relating to the barriers and facilitators of impact.

## Other Sources of Information

We obtained information from AHRQ on the numbers of downloads from the AHRQ Web site and orders from the AHRQ clearinghouse. These data reveal trends in dissemination and use of the reports rather than information on the extent of impact.

We reviewed AHRQ’s list of “articles of interest” (http://www.ahrq.gov/news/articles.htm) and compared its entries with the results from the updated article searches. We found very little overlap (two studies for health literacy and none for omega-3). The AHRQ “articles of interest” search is designed to be broad rather than focused. It identifies studies that cite AHRQ-funded research or contracts, either within the body of the text or in references. Not all the articles that cite AHRQ-funded research would be relevant to an update of the systematic review. We do not include these results in the body of this report.