# Introduction

## Background

The mission of the Agency for Healthcare Research and Quality (AHRQ) to improve “the quality, safety, efficiency, and effectiveness of health care for all Americans” (Clancy and Slutsky, 2007, p. xii)1 places AHRQ’s Effective Health Care (EHC) Program squarely in the realm of translating research into practice. Recent increases in funding in comparative effectiveness research have fueled the urgency of widening the pipeline from the EHC Program’s research portfolio to actionable policy, whether that policy is framed in terms of addressing patient care issues or filling gaps in evidence with new research.

The latter expectation (filling research gaps) from the EHC products and from the Evidence-based Practice Centers (EPCs) is relatively new; it has been codified in terms of production of Research Needs documents. An assessment of the first decade of AHRQ’s outcomes and effectiveness research, which was published in 2000, includes a lengthy list of policy-level change agents that may be influenced by AHRQ reports (“health plans, professional organizations, legislative bodies, regulators, accrediting bodies, the media, industry, and patients”), but it does not mention research funders (Stryer et al. 2000, p. 985).2 By 2005, researchers recognized the potential impact of EPC reports on funders and provided anecdotal3 or qualitative4 evidence that they had influenced a variety of stakeholders. We have not, however, uncovered any systematic consideration of barriers to the use of AHRQ’s EPC reports for developing future funding agendas or empirical evidence of the impact of EPC reports on federal, foundation, or industry funding solicitations.

The United Kingdom’s National Institute for Health and Clinical Excellence (NICE), in grappling with the issue of raising the influence of their systematic reviews, published recommendations in 2006 that systematic reviews offer research recommendations in the “EPICOT” framework, that is, evidence, population, intervention, comparator, outcomes, and timestamp of recommendation.5 We are not aware of any empirical assessment of the NICE recommendations.

## Objectives

This methods project has two objectives. The first is to evaluate the impact of EPC systematic reviews on solicited or funded research. The second is to identify factors that are likely to increase the impact of these documents in the future. Thus, this project presents a unique and timely opportunity to evaluate this aspect of EPC work as changes in the program are unfolding. Specifically, the commissioning of Research Needs pilot documents (the first wave was completed in late 2010) represents a change in AHRQ’s expectations for and investment in the EPC program for specifying future research priorities. We anticipate that although these changes will anticipate some of the insights contained in this report, other conclusions from the report will continue to have relevance as the program evolves.

### Definitions of Outcomes and Impact of Future Research Documents

This task is related to a larger question of identifying the outcomes and impact of research, broadly defined. Stryer and Tunis frame research impacts for AHRQ as a triangle, with the base representing studies that result in knowledge generation, or Level 1 impacts. Attribution of impact to these studies is commonly acknowledged to be difficult to do. 2,6 Higher level impacts include changes in programs or policies (Level 2), changes in clinical or patient practice (Level 3), and changes in health outcomes as the apex (Level 4).2

For our task, we focus on lower-level impacts of EPC systematic reviews. By this, we mean effects seen through research that has been either solicited or funded, and changes occurring in federal, state, and private sector (such as hospital or professional society policies and guidelines) programs and policies (Levels 1–2). We are not examining the impact of systematic reviews or comparative effectiveness reviews on either clinical decision making or health outcomes (Levels 3–4) per se; our interest in these changes is to consider their effect on future research.

The effects of EPC reports can have short-, medium-, or long-term outcomes (often taken to be 1–3 years, 4–6 years, and 7–10 years, respectively).7 Evaluations typically reserve the word “impact” for long-term outcomes. For this task, we will focus on short- and medium-term outcomes of future research sections; we anticipate that impact (longer-term outcomes) will be difficult to identify.

### Potential Pathways for Impact

Based on conversations with key stakeholders in the EHC Program and EPC members, we developed and refined an analytic framework (Figure 1). The figure shows potential pathways by which we hypothesize that EPC reviews can influence future research. A body of evidence is the starting point for EPC comparative effectiveness or systematic reviews that then provide research recommendations. Members of Technical Expert Panels (TEPs) and peer reviewers may influence these research recommendations and may be influenced by the report to generate new research ideas. These reviews may be disseminated to stakeholders that set priorities for research (e.g., Agency and NIH program and policy officials, Congress, industry, foundations, other research funders) either directly or via peer-reviewed publications or other products (e.g., media outreach, journal editorials, media op-eds, white papers, policy briefs and forums, academic presentations, informal discussions). Dissemination of this information leads to a heightened awareness of issues and gaps in knowledge and incorporation of research recommendations into funding priorities. Availability of funding, technology, and stakeholder interest, among other factors, influences the process of developing funding priorities.

Figure 1 Analytic framework: processes and activities leading to impact of EPC reviews on future research

Figure 1 shows potential pathways by which we hypothesize that EPC reviews can influence future research. A body of evidence is the starting point for EPC comparative effectiveness or systematic reviews that then provide research recommendations. Members of Technical Expert Panels (TEPs) and peer reviewers may influence these research recommendations and may be influenced by the report to generate new research ideas. These reviews may be disseminated to stakeholders that set priorities for research (e.g., Agency and NIH program and policy officials, Congress, industry, foundations, other research funders) either directly or via peer-reviewed publications or other products (e.g., media outreach, journal editorials, media op-eds, white papers, policy briefs and forums, academic presentations, informal discussions). Dissemination of this information leads to a heightened awareness of issues and gaps in knowledge and incorporation of research recommendations into funding priorities. Availability of funding, technology, and stakeholder interest, among other factors, influences the process of developing funding priorities.

Determination of funding priorities leads to the release of funding solicitations and, then, to studies being funded. Completion of these investigations (and, usually, publication of the results) eventually adds to the body of evidence, and may prompt updates of the review. Of course, many factors outside this logic model may affect research funding decisions, such as activities by advocacy groups, advances in basic science, changes in organization structure, or legislative changes such as the recent passage of the Patient Protection and Affordable Care Act.

Based on this analytic framework, we developed an evaluation logic model (Figure 2), using the standard evaluation framework that identifies inputs, outputs, and outcomes. Impact refers to both outputs and outcomes.8 In this scheme,

- inputs are resources, contributions, investments that go into the program;
- outputs are activities, services, events, and products that reach people who participate or who are targeted; and
- outcomes are results or changes for individuals, groups, communities, organizations, or systems.

Figure 2 Evaluation logic model for evaluating impact of EPC reports on research outcomes

Figure 2 shows an evaluation logic model for evaluating the impact of EPC reports on research outcomes. This standard evaluation framework identifies inputs, outputs, and outcomes, in response to AHRQ’s mission (to improve the quality, safety, efficiency, and effectiveness of health care for all Americans); vision (to foster and support research that helps America’s health care system provide access to high-quality, cost-effective services and to be accountable and response to consumers and purchasers); and goals (measurable improvements in health care in America). Inputs include AHRQ (leadership and funding and partnership with other institutions), the EPCs (clinical/substantive experts, systematic review experts, and tools to identify gaps or deficiencies in the literature), and stakeholders (key informants, technical experts, and public input). Outcomes include both activities and participants. Activities include summarizing results; identifying gaps and deficiencies in the evidence; producing systematic reviews, journal articles, and other written products; collaborating and consulting with stakeholders and AHRQ; disseminating findings; and collaborating with policy or decision-making bodies. Participants include EPC staff, policy officials (decisionmakers on resource allocation across disciplinary areas), program staff (decisionmakers on funding for gaps and opportunities within disciplinary areas), foundations, Congress, industry, other funders, investigators, and members of the scientific and popular media. Outcomes may be short-term (1–3 years), medium-term (4–6 years), and long-term (7–10 years). Short-term outcomes include knowledge generation through heightened awareness of issues and gaps in knowledge. Other short-term outcomes include funding priorities and policy or practice guidelines that are influenced by or include report recommendations. Medium-term outcomes include knowledge generation through filling gaps in the evidence through new studies that are either investigator-initiated or in response to requests for funding. Long-term outcomes include improvements in the quality, safety, efficiency, and effectiveness of health care through changes in clinical or patient practice and health outcomes.

Specific challenges for empirical measurement of the effect that EPC reports might have on the funding and framing of new research include fluctuations in the external funding environment, the time lag between publication of the EPC report and release of solicitations for research applications, and the lack of visibility of planning processes within funding agencies to outsiders.

## Key Questions

Based on our objectives, analytic framework, and the logic model, we ask the following key questions (KQs):

- Key Question 1. What is the impact of future research sections from EPC reports on solicited or funded research?
- Key Question 2. What best practices or elements of the future research sections are likely to increase the impact of future research sections in EPC reports on future research?

In addressing KQ 1, we acknowledge that the effects of EPC reports might occur directly through direct dissemination of the reports and subsequent filling of evidence gaps that the future research needs sections of the reports identify; they could also occur indirectly through other pathways, which we will seek to elucidate. As suggested by the logic model, we anticipate that EPC reports can have impact in the short term through both heightened awareness of issues and gaps in knowledge and influence on funding priorities and policy or practice guidelines. In the medium term, we anticipate that EPC reports can have effects through the commissioning of new research that fills specific, EPC-identified gaps. In the long term, EPC reports can influence improvements in the quality, safety, efficiency, and effectiveness of health care that then lead to new areas of research.

In answering KQ 1, we will seek information on barriers and facilitators of the pathways for impact. Examining these barriers and facilitators will help us to answer KQ 2. In answering KQ 2, we will focus on the impact of the reports on future research; although changes to elements of the report may improve the overall impact of the report, the focus of KQ 2 is the impact of the project on future research.

### Selected Case Studies

We selected two systematic reviews as case studies for this analysis: the 2004 report on literacy and health outcomes9 and the 2004 reports on omega-3 and cardiovascular disease (CVD).10,11 The methods chapter of this report provides further details on the selection of these case studies.

Literacy and health outcomes. The Berkman et al. 2004 report on literacy and health outcomes examined (1) whether literacy skills were related to use of health care services, health outcomes, costs of health care, and disparities in health outcomes or health care service use according to race, ethnicity, culture, or age, and (2) for individuals with low literacy skills, what were effective interventions to improve use of health care services, improve health outcomes and/or health care service use overall and among different racial, ethnic, cultural, or age groups, and affect the costs of health care.9

The report concluded that “low literacy is associated with several adverse health outcomes, including low health knowledge, increased incidence of chronic illness, poorer intermediate disease markers, and less than optimal use of preventive health services. Interventions to mitigate the effects of low literacy have been studied, and some have shown promise for improving patient health and receipt of health care services” (Berkman et al. 2004, p. vi).9

Berkman and colleagues offered the following research recommendations:9

- Conduct research on factors that mediate the relationship between literacy and important health outcomes. For instance, one question is whether poor reading ability causes adverse health outcomes or is a marker for other problems, such as low socioeconomic status, poor self-efficacy, low trust in medical providers, or impaired access to care.
- Perform more prospective cohort studies that measure changes in outcomes and literacy over time. The aim was to provide a greater understanding of the relationships among literacy, age, and health outcomes and the extent to which changes in health status actually affect literacy.
- Further develop measurement techniques for low-literacy populations.
- Test whether measuring or stratifying outcomes by numeracy provides additional predictive ability for health outcomes versus measuring and stratifying outcomes by literacy alone.
- Conduct studies linking short-term knowledge changes to important health outcomes.
- Carry out analyses to isolate the individual effect of elements of multicomponent interventions.
- Document the importance of low patient literacy in chronic illness programs.
- Study the extent to which interventions designed to allay the effects of low literacy are effective compared to the effects of other interventions in improving health outcomes.
- Stratify results of intervention studies by literacy level.
- Mount studies on provider-patient communication interventions that go beyond written materials.
- Evaluate further the concept of health literacy and its role beyond reading ability (or scores on reading ability).

Omega-3 and cardiovascular disease. The Tufts EPC produced a three-part report on omega-3 fatty acids and cardiovascular risk.10–12 For the purposes of this review, we included the two reports that focused on outcomes and risk factors in humans;10,11 we excluded the omega-3 report that focuses on arrhythmogenic mechanisms in animals and isolated organ/cell cultures.12

The Wang et al. report was the first of the three-part report on this topic and assessed the benefits of omega-3 fatty acid supplements or fish consumption on various CVD outcomes and the adverse events associated with intake of omega-3 fatty acid supplements.13 The report concluded that “consumption of omega-3 fatty acids from fish or from supplements of fish oil reduces all cause mortality and various CVD outcomes. The evidence for ALA [alpha-linolenic acid] supplements is sparse and inconclusive. The adverse events due to consumption of fish oil or ALA supplements appear to be minor” (Wang et al., 2004, p. vi).14

Wang et al. offered the following research recommendations (pp. 99–100):

- “In general, future studies of omega-3 fatty acids should include the following:
  ○ Omega-6/omega-3 ratio should always be estimated and reported.
  ○ Attempts should be made to determine the effect of higher fish intake on the consumption of other foods in the diet, specifically meat and cheese (sources of saturated fat).
  ○ Future prospective cohort studies and diet trials on fish consumption should place special emphasis on collecting data on fish consumed, type of fish, and method of preparation.
- Well-designed, multicenter RCTs [randomized controlled trials] are needed to assess the effect of omega-3 fatty acid consumption on CVD outcomes in primary and secondary prevention settings. The trial design should include a period of long-term followup for 3 to 5 years so that long-term effects of omega-3 fatty acids can be monitored.
- Additional research should address questions about the effect of omega-3 fatty acid consumption on CVD outcomes in specific populations, including patients with diabetes and other chronic diseases.
- The potential effect of ALA is unknown. Current data sets are of poor quality and are too limited for adequate assessment. More trials are needed to confirm or report the effect of ALA, separate from fish or fish oil, on CVD outcomes. We need to know more about the potential interaction of ALA with EPA+DHA [eicosapentaenoic acid and docosahexaenoic acid].
- The relative effect of ALA versus fish oil is not well defined. Comparative trials between these two supplements should be conducted. Given the abundance of soybean and canola oils relative to fish in the diet, it would be useful to understand the economic and ecological impact of increased fish intake, and the potential to initiate change in US dietary patterns.”

The Balk et al. report assessed the consumption of omega-3 fatty acids on various CVD risk factors and intermediate markers of CVD in healthy people and people with dyslipidemia, diabetes, or known CVD. The report noted that “a large, consistent beneficial effect of omega-3 fatty acids was found only for triglyceride levels. Little or no effect of omega-3 fatty acids was found for a variety of other cardiovascular risk factors and markers of cardiovascular disease. The benefits of omega-3 fatty acids on reducing cardiovascular disease are not well explained by the fatty acids’ effects on the cardiovascular risk factors we examined. A strong, linear association was found across studies between omega-3 fatty acid intake and tissue levels” (Balk et al., 2004, p. vi).13

Balk et al. identified the following research recommendations (p. 116):

- “Future studies on CVD risk factors and intermediate markers of CVD should address the question of possible differences in the effect of omega-3 fatty acids in different subpopulations and as related to different covariates, including dose and duration of intake.
- The potential effect of ALA (18:3 n-3) is unknown. More multicenter trials are needed to assess the effect of ALA, separate from the effect of EPA+DHA, on CVD risk factors.
- Additional research is needed to clarify the effect of omega-3 fatty acids on markers of glucose tolerance. Specifically, sufficiently large trials are needed that perform appropriate sub-analyses to determine the cause of heterogeneity in effect across studies.
- The total dietary omega-6 to omega-3 fatty acid ratio should be estimated, reported, and analyzed in terms of its effect on outcomes and its association with any effect of omega-3 fatty acid treatment.
- Future research should attempt to determine the effect of higher fish intake on the consumption of other foods in the diet, specifically sources of saturated fat such as meat and cheese.
- Future prospective cohort studies and diet trials on fish consumption should place special emphasis to collecting data regarding the quantity and type of fish consumed and the method of preparation.”

## Organization of the Remainder of the Report

Chapter 2 describes the methodological constraints and approaches to evaluating the impact of research; it gives our specific indicators and measures and describes our methods to describe each outcome. Chapter 3 first presents the findings on KQ 1, that is, the impact of future research sections from EPC reports on solicited or funded research. It then compiles evidence on KQ 2, that is, factors likely to alter the impact of future research sections in EPC reports. Chapter 4 discusses the implications of the findings on likely pathways that influence the use of the recommendations of the report in future research.