# Executive Summary

## Introduction

The mission of the Agency for Healthcare Research and Quality (AHRQ) to improve “the quality, safety, efficiency, and effectiveness of health care for all Americans” places AHRQ’s Effective Health Care (EHC) Program squarely in the realm of translating research into practice. Recent increases in funding in comparative effectiveness research have fueled the urgency of widening the pipeline from the EHC Program’s research portfolio to actionable policy, whether that policy is framed in terms of addressing patient care issues or filling gaps in evidence with new research.

This methods project has two key questions(KQs). KQ 1 evaluates the impact of Evidence-based Practice Center (EPC)systematic reviews on solicited or funded research (i.e., research funding opportunities or ongoing or completed studies). KQ 2 examines best practices, contextual variables, and other factors that are likely to increase the impact of these documents in the future. Thus, this project presents a unique and timely opportunity to evaluate this aspect of EPC work as changes in the program are unfolding. Specifically, the commissioning of Research Needs pilot documents (the first wave was completed in late 2010) represents a change in AHRQ’s expectations for and investment in the EPC program for specifying future research priorities.

The effects of EPC reports can have short-, medium-, or long-term outcomes (often taken to be 1–3 years, 4–6 years, and 7–10 years, respectively). For this task, we will focus primarily on short-and medium-term outcomes of future research sections; we anticipate that impact (longer-term outcomes) will be difficult to identify.

## Methods

Two basic approaches can be used to answer questions of research impact: historical tracing or forward tracing. With historical tracing, evaluators first identify key advances and then determine the bodies of evidence that influenced the key advances. This particular approach relies heavily on bibliometric techniques (e.g., weight and interconnectedness of citations). Forward tracing starts with specific research and can use a variety of methods, such as case studies, interviews, questionnaires, and bibliometric techniques, to identify both the effects and the pathways for those effects. The historical tracing technique requires a comprehensive bibliographic source, without which results are likely to be biased. The forward tracing technique, through its narrower focus on the specific report for which effects are to be determined, uses a more targeted bibliographic search than historical tracing but may be particularly susceptible to biases relating to attribution. An additional concern with case study analyses, which are often used in forward tracing, is that of selection bias in identifying the cases, which may lead to focusing excessively on positive rather than negative findings or conclusions. We elected to use the forward tracing method and attempted to address specific methodological concerns.

Methodological concerns in identifying the effects of EPC reviews on research (opportunities, priorities, studies begun, and/or studies completed) include the following: (1) attributing impact to the EPC report itself, given that other factors may be influencing policy decisions or changes in research directions or opportunities; (2) accounting for the time lag between the report and the change in research funding priorities or actual investigations; and (3) taking into consideration what might have occurred in the absence of the EPC report. We attempted to answer the two project questions using forward tracing for two case studies. We used a combination of methods: key informant interviews, Web searches, and bibliometric techniques for citation analysis.

In addressing the two key questions and accounting for potential biases, we took the following tasks to be critical: (1) developing an analytic framework to depict and separate, when possible, the pathways for attribution of impact directly to the systematic review as contrasted with its contribution to a larger set of factors that impact future research; (2) stating the considerations weighed in selecting case studies; and (3)carrying out some assessment of funding priorities before and after the publication of the report to avoid a focus on overly positive findings.

Regarding the development and revision of the analytic framework, we explicitly asked each key informant for feedback on the analytic framework and used their input to revise our hypothesized pathways for impact.

We sought nominations for case studies from EPC directors to identify EPC reports known to have had some impact. We identified 16 potential reports. In evaluating each nomination, we highlighted studies that were either so recent or so old as to raise concerns regarding the measurement or attribution of impact. We also identified studies with the potential for a conflict of interest( i.e., the authors of the systematic review would be intimately involved in this evaluation). We consulted with senior AHRQ staff to narrow the selection further.

Two important additional considerations influenced the final selection of the topics: ongoing update activities and variation in the topic. The 2004 report on literacy and health outcomes and the 2004 reports on omega-3 fatty acids and cardiovascular issues were in the process of updates, either formally or as part of a methods project. In addition, each of these projects represented very different types of topics. Health literacy is a broad topic that influences many different substantive areas; omega-3, by contrast, is a much more focused topic. The variation in topics presented an opportunity to explore different pathways for impact.

We addressed the assessment of funding priorities before and after the systematic reviews through reviews of federal Requests for Applications (RFAs) and Program Announcements (PAs) from 1993 to 2010 (a period that includes 11 years of funding before release of the reports and 6 years thereafter). We also asked funders who offered anecdotal evidence of changes in funding priorities to describe the contribution of the AHRQ report to these changes.

### Data Sources for Bibliometric Analysis

Published Literature. We used information provided by our key informants to obtain a list of “first-generation” references—that is, references that were derived directly from the report (peer-reviewed publications drawing upon the reports). We then used ISI Web of Science and PubMed Central sources to obtain information on the weight( i.e., the number of articles referring to the report and first-generation sources) and interconnectedness of citations. We ran searches in these sources for each of the original citations and first-generation citations to obtain the list of second-generation citations.

Solicitations. We searched the National Institutes of Health [NIH] Guide for Grants and Contracts Website for funding opportunity announcements. The Website is limited in its search functionality: no date limits can be set if inactive solicitations are requested. A search for “health literacy” yielded 92 requests for applications (RFAs) and program announcements (PAs) since 1993. Four separate searches of terms related to omega-3 (“omega 3,” “fish oil,” “n-3 fatty acids,” and “omega-3 fatty acid”) yielded 34 unique RFAs and PAs since 1993.

### Update Searches

One methodological limitation of the forward tracing approach is its focus on positive results. Searches for studies in ISI Web of Science of PubMed provide information on weight and interconnectedness of citations, but they cannot provide information on the extent to which the systematic review and its byproducts influenced future research. To understand the extent to which systematic reviews have had impact, a denominator, that is, the number of studies that could potentially have cited the systematic review, is required. As noted earlier, we selected both case studies because they were in the process of being updated. We obtained updated search results for both case studies through personal communication with the update teams. The health literacy update team conducted a full update of the literature and identified 177 new citations from 2003 to 2010 that met inclusion criteria. For omega-3, we understood from personal communication with the team that the update search was an abbreviated search for the 2004 Balk et al. report on cardiovascular risk factors and intermediate markers alone (i.e., the update search did not focus on the Wang et al. report). The intent of the update search was conducted primarily to understand signals for whether the report was ready to be updated rather than to serve as an update of the results. The update team conducted searches only in key journals; these searches yielded 66 new citations that met inclusion criteria.

We obtained full-text articles for each article and reviewed each article for evidence of citation of the systematic review or associated articles. We abstracted data showing how each article cited the systematic review or associated articles. We also reviewed each article and abstraction dually and recorded the context and purpose of the citation.

### Selection and Interviews of Key Informants

We used snowball recruitment to identify and recruit key informants. We intended to interview at least two investigators of the original report, two funders, and two external experts. We began our interviews with the investigators of there ports and were guided by their input in the selection of subsequent key informants. We interviewed a total of six key informants for the literacy and health outcomes case study and seven for the omega-3 case study. The chief purpose of the interviews was to identify (1) relevant funding solicitations and investigator-initiated funding and (2) barriers and facilitators to the use of past reports for developing funding agendas or solicitations. We used N Vivo to analyze the data.

### Other Sources of Information

We obtained information from AHRQ on the number of downloads from the AHRQ Web site and orders from the AHRQ clearinghouse.

## Results

### Impact of EPC Reports (KQ 1): The Literacy and Health Outcomes Case Study

Inputs. The American Medical Association (AMA) requested the report on literacy and health outcomes; AHRQ funded it. Principal authors included systematic review expert Nancy Berkman, Ph.D., of RTI International, and substantive experts Darren DeWalt, M.D., M.P.H., and Michael Pignone, M.D., M.P.H., of UNC.

Outputs. In January 2004, AHRQ released the report on literacy and health outcomes. The authors also produced two journal articles.

Short-term impact: Increased awareness of issues. Our analysis of the short-term impact of this report comes from several sources: evidence of citation of the report through searches from the updated reports, ISI Web of Science, and PubMed Central; dissemination through downloads and orders of the AHRQ report; qualitative reports of media interest; and heightened collaboration in the field.

Citation of the report. Our analysis of the literature from the health literacy update report suggests widespread citation of the 2004 report. More than one-third of the articles(60 of 168) in the update of the report cited the 2004 report or its derived articles.

Media coverage. The 2004 report on literacy and health outcomes generated some media interest. EPC investigators, along with authors of a report from a committee of the Institute of Medicine (IOM) on health literacy, presented their findings at the National Press Club in Washington, D.C.

Dissemination of the AHRQ report. Over time, interest in the executive summary in both PDF and HTML formats continues to be quite high (2004 through October 2010)through downloads (3500–4900)

Collaboration. EPC investigators were able, despite some constraints, to collaborate to fill research gaps following publication of the report. Some key informants believed that the EPC investigators were not funded either to disseminate the reports more broadly or to maintain systematic contact with policymakers or key stakeholders; this problem made it difficult for them to build on report findings. However, several of the EPC investigators were in a position, as a result of their prominence in the field independent of the report, to collaborate on future health literacy research.

Short-term impact: Influence on funding priorities. Of the 92 RFAs and PAs identified through our searches, 17 (funded by a variety of agencies within NIH and AHRQ) preceded the release of the report. This tally suggests that the funders were pursuing active support of this field even before the release of the systematic review. Of the remaining 75 RFAs and PAs, 4 cite the AHRQ report.

In keeping with these findings, although key informants believed that the EPC report had a role in increasing funding for health literacy, generally they were unable to identify many specific requests for funding or funding prioritization documents that referred to the report. They noted several reasons: first, report findings were not compatible with future research. Second, the very nature of the topic is difficult to translate into funded research. Health literacy is relevant across the entire health care continuum, but it is not specific to any particular clinical area. Third, dissemination could have been planned better and targeted to end users. Fourth, the report itself could have been easier to use.

Short-term impact: Influence on policy or practice guidelines. Key informants noted that although some organizations have developed policies about health literacy since 2004, these developments are difficult to attribute to the EPC report. Key informants noted that the report’s failure to change policy and practice guidelines in any substantial way may be more the result of the then-nascent state of research and literature on health literacy than the shortcoming of the report.

Medium-term impact: Knowledge generation. Key informants repeatedly referred to the AHRQ EPC report as a foundational document. We found that 13 of 168 citations in the update search referred to the 2004 report as a means of illustrating that their research addressed a gap identified by the report. An additional three studies referred to the AHRQ report and its products to support their own conclusions for future research.

In addition to the impact on other investigators, the report had an impact on the future research of the EPC investigators who wrote it. Independent of the EPC report, the EPC content experts were pursuing research in health literacy. However, their involvement in the report had two impacts. First, it helped to clarify for them the status of health literacy research and the gaps that needed to be filled. Second, it was one of many reports that provided them with a strong reputation for health literacy research. They were able to parlay their experience into future work and prominence in the field: serving on review panels, writing editorials, and presenting and planning major conferences.

Long-term impact: Changes in clinical or patient practice. In general, key informants felt that the report’s impact on clinical and patient practice was tangential at best. Most key informants saw the report as several steps removed from changes at the clinical or patient practice level. Some of the reasons that the report has not changed clinical or patient practice can be attributed to the report itself. Several key informants noted that the report was not written for clinicians; the comprehensive review of literature is helpful for researchers but unwieldy for clinicians. One key informant suggested the creation of complementary documents created specifically with clinicians in mind.

Long-term impact: Changes in health outcomes. The key informants generally agreed that if the report had any effect on health outcomes, it was indirect.

## Impact of EPC Reports (KQ 1): The Omega-3 and Cardiovascular Disease Case Study

Inputs. The omega-3 reports on CVD were part of a series of reports requested and funded by the Office of Dietary Supplements(ODS), National Institutes of Health; two focused on humans and a third on animals and isolated/cell cultures.

This methods project used the two reports(Balk et al. 2004 and Wang et al. 2004) focusing on outcomes in humans, with the exception of one indicator for short-term impact (citation of the report or articles) and one for medium-term impact (knowledge generation). For these two indicators, we derived information from an ongoing update of the literature by Balk and colleagues for the Balk et al. 2004 report. No similar resource was available for the Wang et al. report; conducting an update of the literature for the Wang et al. report would have been outside of the scope of this Methods Future Research Needs project.

Outputs. In March 2004, AHRQ released both omega-3 reports on CVD and on CVD risk factors. The CVD report led to a journal article. The CVD risk factors report resulted in two journal articles. The team then published a methods paper on systematic reviews of nutrition topics based on several omega-3 reports.

After the release of the EPC reports, ODS (the report funder) and the National Heart, Lung, and Blood Institute (NHLBI) organized two workshops to discuss priorities for future funding.

Short-term impact: Increased awareness of issues. We evaluated four measures of short-term impact: citation of the report, media coverage, dissemination of the AHRQ report, and collaboration.

Citation of the report. Our analysis of the literature from the omega-3 update search suggests some citation of the 2004 report. Of 49 articles, seven cite the omega-3 report or subsequent journal articles. Most articles cite the report and the articles to place their findings in context or to establish the state of the science.

Media coverage. AHRQ and ODS orchestrated a press release, which received some media publicity. Several key informants noted coverage from popular media as well as scientific media. Key informants also noted that omega-3 fatty acids have received substantial coverage overall concerning their positive effects.

Dissemination of the AHRQ report. AHRQ’s record of downloads through HTML and PDF formats since the publication of the reports through October 2010 show a peak of interest in the year following the report (with more than 14,000 downloads of the full report on cardiovascular disease); interest leveled off after that point. For both reports, the executive summary remains the most consistently sought-after product.

Collaboration. The coinvestigators on this topic who were content experts had substantial expertise before their involvement in the report; thus, the report did not serve as a mechanism to create opportunities for collaboration with their peers on the topic.

Co-investigators who were methodologists (i.e., EPC investigators) did not pursue additional work in this content area, so they did not seek opportunities for collaboration on this specific topic. They did, however, make connections with nutrition experts at Tufts as a result of this work and so expanded their capacity to do nutrition-related reviews.

Short-term impact: Influence on funding priorities. We found 9 RFAs and 25 PAs that cited the term “omega-3,” “fish oil,” “n-3 fatty acids,” or “omega-3 fatty acids.” Four RFAs and two PAs preceded the release of the report. None cited the EPC reports or articles. The low yield of RFAs and PAs was validated by key informants who cited the importance of investigator-initiated research in this field.

As for influence of the report on funding solicitations, as noted earlier, NHLBI and ODS collaborated on two workshops. NHLBI’s first workshop proposed a large clinical trial, but the lack of funding support prevented further evolution of the proposal. The second workshop resulted in a peer-reviewed journal article that was cited by three articles in the update search for the Balk et al. 2004 report and was reported by key informants to be influential in investigator-initiated funding ideas. Our review of citations using ISI Web of Science and PubMed Central found that 39 studies cited the article from the NHLBI workshop. In addition, the workshop served as means of convening experts in the field, who then went on to submit investigator-initiated awards.

ODS conducted an assessment in 2010 of the effect of EPC omega-3 reports on their grant portfolio and found that only one of 20 grants cited the AHRQ report(personal communication). One possible reason for the citation could be that the sole investigator who cited the AHRQ report was involved in the workshop and knew about the reports beforehand.

Key informants noted that the reports lacked specificity, particularly when compared to other reports (e.g., from the IOM) that separate “major” knowledge gaps from noncritical research gaps.

Short-term impact: Influence on policy or practice guidelines. Key informants generally did not believe that the EPC reports had impact on policy and practice guidelines for several reasons. First, the American Heart Association (AHA) guidelines on eating oily fish preceded the reports; the AHA did not change their guidelines based on the reports. Second, no translation of the AHRQ report to clinical recommendations exists. A third explanation is that the evidence base is not compelling to guideline developers. Third, one key informant noted that guideline developers may not always be driven by evidence.

Medium-term impact: Knowledge generation. Two sets of authors cited one of the AHRQ report and two journal articles to illustrate how their studies filled gaps identified by the AHRQ review.

Investigators on the EPC team expanded their portfolio of research in the area of systematic reviews of nutrition topics. Content experts became more involved in systematic review work and related activities, serving on a Technical Expert Panel and on guideline committees. Additionally, the methodological challenges of conducting systematic reviews in the nutrition field spurred the Tufts team to seek additional funding on methods from NIH.

External constraints included funding, the state of current patient practice, and the existing knowledge base among funders and reviewers.

Long-term impact: Changes clinical or patient practice. Key informants noted a substantial change in clinical practice and cited the commonplace use of omega-3 supplements. They noted, however, that this change is attributable not to a single report, but to a body of evidence, with a slow accumulation of data on benefits from 1985 onward (when the New England Journal of Medicine published three studies on omega-3) and limited evidence of harms.

Long-term impact: Changes in health outcomes. Key informants uniformly agreed that they could not make a judgment on whether the EPC report has had an impact on health outcomes. They cited the difficulty of attribution of effect to the EPC report in particular.

## Factors Influencing the Impact of EPC Reports (KQ 2)

Key informants discussed several benefits of the EPC reports. Among these were steps such as providing a foundation for the research community to build on, heightening awareness of the gaps in knowledge, increasing the quality of research, and sparking new directions of research. However, the degree to which these reports were influential and well-received hinged on several factors including marketing efforts, the very nature of the reports, and various other influences external to the EPC domain.

Dissemination involves using multiple venues and media and identifying “champions.” The reports themselves were not easy to read. Key informants suggested expanding the intended reach of reports, improving recommendations for future research, and building on strengths of the systematic review approach. External factors such as the lack of evidence supporting a clear direction for future research, the difficulty of funding research in basic science, and restrictions in the size of the field and number of investigators or lack of overall funding may not be as amenable to change. Key informants did note the heightened impact of AHRQ reports when their release converges with other seminal reports.

## Discussion

### Impact of EPC Reports on Future Funding (KQ 1)

The impact of EPC reports on future funding can be conceptualized narrowly, as being limited to knowledge generation, that is, new studies inspired by the gaps identified by the systematic review. A more comprehensive framework, and one that key informants reinforced, specifies pathways for impact that include other outcomes such as increased awareness or changes in policy and practice that may then spur new research.

The impact of the selected EPC case studies is demonstrably greater on short-term outcomes, that is, greater awareness of the issues, than on medium-term (such as the generation of new knowledge) or long-term outcomes (such as changes in patient practice or health outcomes). Articles identified in the relevant updates of the literature searches cited reports and articles from both case studies in high numbers.

We did not uncover evidence of impact of EPC reports on long-term outcomes; however, long-term effects may take longer than the 6 years that have elapsed since the publication of the reports for the two case studies. Attributing impact related to long-term outcomes to the EPC reports may be poorly documented.

Our evaluation suggests that the extent of impact of an EPC report will vary based on factors such as the nature of the topic and the timing of the report relative to the development of the field. Systematic reviews that cover a broad scope will likely be cited more frequently than more narrowly specified topics. Reports that summarize findings for an emerging field serve as foundational material for subsequent work.

The degree to which the new research can be directly attributed to the AHRQ reports remains unclear. Neither the literacy report nor the omega-3 reports directly resulted in allocation of dedicated funds for future research for that topic. In the case of health literacy, for example, the initial PAs did not cite the AHRQ report until the second round of funding. Nevertheless, the reports did influence the way that the EPC investigators, other investigators, and funders approached the topics.

### Elements That Contribute to the Impact of EPC Reports (KQ 2)

Our interviews with key informants suggest that factors that contribute to or detract from the impact of EPC report are associated with the report itself, its dissemination, and the environment into which it is issued. AHRQ has already identified some of these challenges and has instituted (or is in the process of implementing) several specific solutions. Some appear in the new round of funding for future research documents; others are steps that EPCs can take by following revised methods for systematic reviews and comparative effectiveness reviews (Table A).

Table A Ongoing and newly proposed changes to future research sections of systematic reviews

Ongoing changes
• Greater specificity in future research needs (including providing a sense of relative urgency about specific recommendations)
• Greater involvement of funders and stakeholders in the research recommendations
• Improvements in readability of the systematic review
• Greater specificity in future research needs (including providing a sense of relative urgency about specific recommendations)
Additional changes suggested by key informants and results of the report
• Newly proposed changes
• Dissemination plan that involves EPC investigators and a “champion” funder
• Careful consideration of likely audience and impact when scoping the topic
• Balanced investigative team
• Targeted dissemination to funders and investigators
• Outreach to other funding agencies
• Greater funding support of journal articles (the most widely cited source of AHRQ-support research

### Limitations

The two case reports selected for this methods project represent different types of content areas and, therefore, provide some variation in understanding how EPC reports may have impact on future research. Nevertheless, these two case studies are limited in applicability to other reports in the EPC program.

The methods used in this report are best suited to identifying impacts through short-term and medium-term pathways. Our methods and timeframe may have influenced our ability to find evidence of long-term impacts.

## Conclusions

The case studies of literacy and health outcomes and omega-3 fatty acid supplements illustrate the multiple and often nonlinear pathways by which EPC reports can have short-to long-term impact on future research. Although these pathways are not entirely predictable, common themes emerged from our work along several dimensions: the importance of the breadth, specificity, and “readiness” of the topic for more research; ongoing developments in the field; availability of funding; and the active engagement of champions. AHRQ and the EPCs may be able to improve the likelihood of impact by creating more targeted products, planning for and expanding dissemination activities, improving the readability and other attributes of the reports themselves, and actively involving funders early on and throughout the process of creating and publishing the reviews.

## References

Please refer to the reference list in the full report for documentation of statements contained in the Executive Summary.