# Discussion

## Impact of EPC Reports on Future Research Funding (KQ 1)

The impact of EPC reports on future research funding can be conceptualized narrowly, as being limited to knowledge generation, that is, new studies inspired by the gaps that a systematic review identifies. A more comprehensive framework, and one that key informants reinforced, includes pathways for impact that include other outcomes such as increased awareness or changes in policy and practice that may then spur new research.

The impact of the selected EPC case studies is demonstrably greater on short-term outcomes, that is, greater awareness of the issues, than on medium-term (such as the generation of new knowledge) or long-term outcomes (such as changes in patient practice or health outcomes). The articles identified in the relevant updates of the literature searches cited reports and articles from both case studies in high numbers. As noted earlier, as many as 60 of 168 articles (36 percent) that were included in an update of the health literacy report cited the report and/or articles from the 2004 report. Similarly, 7 of 49 articles (14 percent) identified for an update of the Balk et al. report cited the 2004 report and associated articles. Such citations were intended primarily to support the problem statement, illustrate the state of the science, or place findings in context. A smaller number of included articles from the update searches used the citation to the AHRQ reports and associated articles to explain how their work filled gaps that the report identified (16 of 168, in the case of health literacy and 2 of 49 studies, in the case of omega-3).

We did not uncover evidence of impact of EPC reports on long-term outcomes. We emphasize, however, that important constraints related to timing and attribution imply that the absence of evidence cannot be interpreted as absence of impact. Long-term effects may take longer than the 6 years that have elapsed since the publication of the reports used for the two case studies. Attributing impact related to long-term outcomes back to the EPC reports may be poorly documented: the feedback from our respondents suggests that the longer a report is in existence, the more it is likely to be part of the “received wisdom” or common knowledge and the less likely it is to be cited.

In addition to the question of the type of impact (short-, medium-, or long-term), questions arise regarding the extent of impact, i.e., the degree to which impact can be attributed directly or specifically to the AHRQ reports. Our evaluation suggests that the extent of impact of an EPC report will vary, based on factors such as the nature of the topic and the timing of the report relative to the development of the field. Systematic reviews that cover a broad scope will likely be cited more frequently than more narrowly specified topics. Reports that summarize findings for an emerging field serve as foundational material for subsequent work.

The degree to which the new research can be directly attributed to the AHRQ reports remains unclear. Neither the literacy report nor the omega-3 reports directly resulted in allocation of dedicated funds for future research for that topic. In the case of health literacy, for example, the initial program announcements did not cite the AHRQ report until the second round of funding.

Nevertheless, the reports did influence the way that the EPC investigators, other investigators, and funders approached the topics. They also led to more research through tangential routes: in the case of omega-3, the involvement in the reports led the Tufts EPC to seek funding and specialize in reviews relating to nutrition. Similarly, involvement in the health literacy report spurred EPC investigators to seek funding for those gaps.

Our interviews with key informants, and the observations they made about barriers or ways to overcome those barriers, led us to revise the analytic framework for each case study (Figures 8 and 9). In our revised analytic frameworks, we added boxes and links to illustrate the role of experts, stakeholders, and funders before the commissioning of the report and their continued involvement (often entirely independent of the EPC report) that may significantly advance the field through the creation of other products, development of investigator-initiated research, and active championing and leveraging of funding opportunities.

Figure 8 Analytic framework of the processes and activities leading to impact of the 2004 report on literacy and health outcomes on future research

Figure 8 illustrates a revised analytic framework depicting the processes and activities leading to impact of the 2004 Literacy and Health Outcomes report on future research. The identification of health literacy as a public health problem in the Healthy People 2010 report accompanied by the interests of experts, stakeholders, and funders helped to propel the body of evidence for the review. In addition, a parallel stream of other products and activities such as the IOM report, primary research and dissemination by EPC investigators, national assessment of health literacy, and the HHS health literacy action plan helped disseminate findings of the health literacy report. Funders also leveraged and identified other funding opportunities, leading to more funded solicitations for health literacy research.

Figure 9 Analytic framework of the processes and activities leading to impact of the omega-3 and cardiovascular disease reports on future research

Figure 9 illustrates a revised analytic framework depicting the processes and activities leading to impact of the 2004 omega-3 and cardiovascular disease reports on future research. The identification of omega-3 as a research issue accompanied by the interests of experts, stakeholders, and funders helped to propel the body of evidence for the review. In addition, a parallel stream of other products and activities such as primary research and dissemination by EPC investigators, the NIH and ODS workshop, and peer-reviewed publications helped to disseminate the findings of the omega-3 and cardiovascular disease reports. Funders also leveraged and identified other funding opportunities, leading to more funded solicitations for omega-3 research.

Depending on the topic, the pathways for research may vary. For instance, a funding solicitation from the National Institute of Health for health literacy led to several funded studies. For omega-3, no funding solicitation was issued; investigator-initiated funding resulted in new studies.

## Elements That Contribute to the Impact of EPC Reports (KQ 2)

Our interviews with key informants suggest that factors that contribute to or detract from the impact of EPC report are associated with the report itself, its dissemination, and the environment into which it is issued. AHRQ has already identified some of these challenges and has instituted (or is in the process of implementing) several specific solutions. Some appear in the new round of funding for future research documents; others are steps that EPCs can take by following revised methods for systematic reviews and comparative effectiveness reviews (Table 7).34

Table 7 Ongoing and newly proposed changes to future research sections of systematic reviews

Ongoing changes
• Greater specificity in future research needs (including providing a sense of relative urgency about specific recommendations)
• Greater involvement of funders and stakeholders in the research recommendations
• Improvements in readability of the systematic review
• Greater specificity in future research needs (including providing a sense of relative urgency about specific recommendations)
Additional changes suggested by key informants and results of the report
• Newly proposed changes
• Dissemination plan that involves EPC investigators and a “champion” funder
• Careful consideration of likely audience and impact when scoping the topic
• Balanced investigative team
• Targeted dissemination to funders and investigators
• Outreach to other funding agencies
• Greater funding support of journal articles (the most widely cited source of AHRQ-support research

### Development of a Dissemination Plan

In early years of the EPC program, investigators were asked to develop a dissemination plan for the report. A return to such an approach in the design phase (during topic refinement) will allow EPC investigators, AHRQ, and other stakeholders to specify and plan for a wide but appropriate set of methods of dissemination. Such advance planning can, take target audiences into account, and identify a “champion” funder or funders. The enhanced role of the peer and public comment in the Effective Health Care Program may be channeled for improved dissemination. For example, the technical expert panels (TEP), peer reviewers, and the public can be routinely asked whether and how they plan to disseminate AHRQ reports.

### Consideration of Audience and Impact When Scoping the Topic

The heightened involvement of EPCs in recent months in topic nomination development and topic refinement provides an opportunity for shaping the topic to achieve greater impact on future research. An important consideration for AHRQ, the nominators, and the EPC is how to balance breadth of review topics (i.e., scope of the review and its key questions) with specificity in those topics. The balance of these two perspectives may involve a tradeoff when impact on future research is balanced against impacts on clinical practice and patient outcomes.

Narrowly framed topics allow for a focused summary of clinical issues and a clearly specified target audience, but they may not have as wide-ranging implications for future research. Broadly framed topics have wider applicability and, therefore, could potentially offer wider implications for future research. In addition, broadly framed topics may generate cross-fertilization across disciplines. The potential benefits from broadly framed topics may not be realized when research gaps lack adequate specificity or when such topics suffer from lack of leadership or ownership in the topic and, thus, lack of dedicated funding. A closer examination of these issues during topic refinement will allow AHRQ and EPCs to involve the appropriate stakeholders in dissemination of the report.

### Balanced Investigative Team

Key informants noted the high regard for EPC reports, driven in part by the involvement of methodologists with no preconceived biases. At the same time, key informants for both case reports cited the lack of specificity of research recommendations; they suggested that a possible reason was lack of involvement of authors in the front lines of the research. EPCs may need to shift the balance of the investigative team over time to include more content experts in developing research recommendations.

### Targeted Dissemination to Funders and Investigators

A related concern is the development of short, practical guides or one-page fact sheets for funders and investigators about future research needs after the report is completed. These would complement ongoing products for practitioners and consumers.

Our findings clearly demonstrate that journal articles far outweigh other types of products in influencing future research. Targeted dissemination to other investigators requires the support of journal article preparation and participation in venues, such as the omega-3 case NHLBI workshops.

### Outreach to Other Funding Agencies

AHRQ will need to garner external support from other agencies and organizations to raise awareness of the topic and to fund recommended research. Early outreach may require engaging appropriate staff from sister agencies (or foundations, or industry, as appropriate) as the report is being put into final form.. Their continued involvement through the future research needs projects could enhance the likelihood of impact of EPC reports.

## Limitations

The two case reports selected for this methods project represent different types of content areas and, therefore, provide some variation in understanding how EPC reports may have impact on future research. Nonetheless, they are limited in applicability to other reports in the EPC program.

The impact from EPC reports on future research may occur within a few months or years after the release of the report, as a consequence of improved knowledge about gaps in the research and recommendations for future research. The methods used in this report are best suited to identifying impacts through short-term and medium-term pathways. Our analytic framework anticipated that EPC reports could have long-term impacts on health outcomes and changes in clinical practice that could then result in additional research, but we found no evidence of long-term impacts through EPC reports.

The logic model in this report is one of several potential approaches to framing potential research impacts. Another method of conceptualizing impact could start with the intended audience and then identify pathways that lead to potential impact. As one reviewer noted, three groups, which intersect but are not completely overlapping, may be of particular interest. One group sets “macro” research policy (e.g., those who must make decisions about research resources and allocations across a spectrum of research disciplinary areas, maintaining balance across competing claims for those resources); another is a group that might be said to focus more on “micro” research policy (e.g., decisionmakers about beginning or continuing funding within a given topical or disciplinary area); and finally, a third group comprises those in the research community who actually undertake the research and contribute to the knowledge base for whom technical challenges in the current state of science (as contrasted with resources per se)may be the guiding concern. Adopting one specific approach over other approaches, for repeated evaluations of impact, requires considered input from ARHQ and the EPCs.

One question that arises is how best to frame an operational definition of impact on future research in the longterm. Our metrics, methods, and timeframe may have influenced our ability to find evidence of long-term impacts. Other metrics might include the intensity of knowledge translation as a whole; this idea involves building more efficiently on what is already known. Intensity may include both the pace and volume of new research, programs, and research capacity. A key consideration in interpreting these metrics will continue to be that of separating attribution from contribution.

In the physical and biological sciences, failed trials may lead to new ways of thinking to that may lead to breakthroughs in subsequent rounds of research. Similarly, systematic reviews that are unable to come to conclusions because of insufficient evidence may spur new research in topics that have major clinical uncertainties but may never be cited. Identifying appropriate metrics to account for both intended and unintended pathways of impact will continue to be challenging. Finally, during the design of this project, we were not aware of other reports that sought to understand the impact of EPC reports on future research. We were limited by available data and indicators. Future monitoring and evaluation of impact would benefit from a routine, robust, and relatively low-effort assessment, such as citation analysis of included articles in updates of EPC reports, to understand whether and how EPC reports are being used to shape the field.

## Conclusions

The case studies of literacy and health outcomes and omega-3 fatty acid supplements illustrate the multiple and often nonlinear pathways by which EPC reports can have short- to long-term impact on future research. Although these pathways are not entirely predictable, common themes emerged from our work along several dimensions: the importance of the breadth, specificity, and “readiness” of the topic for more research; ongoing developments in the field; availability of funding; and the active engagement of champions. AHRQ and the EPCs may be able to improve the likelihood of impact by creating more targeted products, planning for and expanding dissemination activities, improving the readability and other attributes of the reports themselves, and actively involving funders early on and throughout the process of creating and publishing the reviews.