# Appendix E Key Informant List

Table E1 List of Key Informants

Omega-3 and cardiovascular disease case study | Literacy and health outcomes case study
Ethan Balk, M.D., M.P.H. Tufts University Evidence-based Practice Center Boston, MA | Cynthia Baur, Ph.D. Centers for Disease Control and Prevention Atlanta, GA
Beth Collins Sharp, Ph.D., R.N. Agency for Healthcare Research and Quality Rockville, MD | Nancy Berkman, Ph.D. RTI International Research Triangle Park, NC
Rebecca Costello, Ph.D., F.A.C.N. National Institutes of Health-Office of Dietary Supplements Bethesda, MD | Cindy Brach, Ph.D., M.P.P. Agency for Healthcare Research and Quality Rockville, MD
William Harris, Ph.D. Sanford Health Sioux Falls, SD | Darren DeWalt, M.D., M.P.H. University of North Carolina School of Medicine Chapel Hill, NC
Penny Kris-Etherton, Ph.D., R.D., F.A.H.A. Pennsylvania State University University Park, PA | George Isham, M.D., M.S. HealthPartners Bloomington, MN
David Lathrop, Ph.D., F.A.H.A. National Heart, Lung, and Blood Institute Bethesda, MD | Joanne Schwartzberg, M.D. American Medical Association Chicago, IL
Alice H. Lichtenstein, D.Sc. Tufts University Boston, MA