# Appendix D Results of Update Search

Appendix D contains four tables: D1, D2, D3, and D4. Tables D2 and D4 record how studies published after the release of the AHRQ report use the report and related citations. Tables D1 and D3 serve as codes for Tables D2 and D4, respectively. Table D2 lists all the articles identified as being relevant for inclusion during an update of the Literacy and Health Outcomes report and provides the author, year, and title of the article. The column titled “References” lists whether or not the article cited the original AHRQ report, subsequent articles, or other work by the EPC investigators. If the article cite done or more of these references, the column entitled “Reference” also lists a numerical code (Table D1 provides the key to the code). The “Text” column provides the exact string of text that cites the AHRQ report, subsequent articles, or EPC investigators and includes either a numbered citation or the author’s last name. Because the entry in the “Text” column is a direct quote from the article, the format of the citations may appear in superscripts or brackets as numbered references or in parentheses with the author’s last name, with the full citation appearing in the reference list for each entry in the table. Dueto the difficulty of reproducing the entire reference list from each article in the table, we highlighted the exact string of references to the original AHRQ report, subsequent articles, or other work by EPC investigators in bold in brackets.

Table D1 Key to review of update of health literacy

| Citation
1 | Berkman ND, DeWalt DA, Pignone MP, Sheridan SL, Lohr KN, Lux L, Sutton SF, Swinson T, Bonito AJ: Literacy and health outcomes, summary, evidence report. Rockville, MD, Agency for Healthcare Research and Quality, 2004 (Tech. Assessment no. 87)
2 | DeWalt, D.A., Berkman, N.D., Sheridan, S., Lohr, K.N., & Pignone, M.P. (2004). Literacy and health outcomes: A systematic review of the literature. Journal of General Internal Medicine, 19, 1228–1239.
3 | DeWalt DA, Boone RS, Pignone MP. Literacy and its relationship with self-efficacy, trust, and participation in medical decision making. Am J Health Behav. 2007;31 Suppl 1:S27–35. [PMID: 17931133]
4 | DeWalt DA, Pignone MP. Reading is fundamental: the relationship between literacy and health [Editorial]. Arch Intern Med. 2005;165:1943–4. [PMID: 16186462]
5 | Pignone MP, Dewalt D. Literacy and health outcomes Is adherence the missing link? J Gen Intern Med. 2006;21(8):896–7.
6 | DeWalt, D. A., Pignone, M., Malone, R., Rawls, C., Kosnar, M. C., George, G., et al. (2004). Development and pilot testing of a disease anagement program for low literacy patients with heart failure. Patient Education and Counseling, 55(1), 78–86.
7 | DeWalt DA, Malone RM, Bryant ME, et al. A heart failure self-management program for patients of all literacy levels: a randomized, controlled trial [ISRCTN11535170]. BMC Health Serv Res. March 13 2006;6:30.
8 | DeWalt DA, Pignone M, Malone RM, Bryant B, Felix K, Corr K, et al. Randomized controlled trial of a primary care-based heart failure disease management program for patients with low literacy. J Gen Intern Med 2004;19(s1):203.
9 | Pignone M, DeWalt DA, Sheridan S, Berkman N, Lohr KN. Interventions to improve health outcomes for patients with low literacy. A systematic review. J Gen Intern Med. 2005;20:185–92.
10 | Dewalt DA, Pignone M. Health literacy and health outcomes: overview of the literature. In: Schwartzberg J, VanGeest J, Wang C, editors. Understanding health literacy – implications for medicine and public health. American Medical Association; 2005. p. 205–28.
11 | DeWalt DA, Dilling MH, Rosenthal MS, Pignone MP. Low parent literacy is associated with worse asthma care measures in children. Ambul Pediatr 2007;7(January–February):25–31.
12 | DeWalt DA, Boone RS, Pignone MP. Literacy and its relationship with self-efficacy, trust, and participation in medical decision making. Am. J. Health Behav. 2007; 31: S27–S35.

Table D2 Purpose of citation for health literacy update search

First Author | Year | Title | References | Text | Purpose of citation
Marteleto L. | 2008 | Sexual behavior, pregnancy, and schooling among young people in urban South Africa | None
Torres RY | 2009 | Relationships among health literacy, knowledge about hormone therapy, self-efficacy, and decision-making among postmenopausal health | None
Kalichman SC | 2008 | Association between health literacy and HIV treatment adherence: further evidence from objectively measured medication adherence | None
Grubbs V | 2009 | Health literacy and access to kidney transplantation | None
Lincoln A | 2008 | Limited literacy and psychiatric disorders among users of an urban safety-net hospital's mental health outpatient clinic | 1 | The recent Agency for Healthcare Research and Quality evidence review, “Literacy and Health Outcomes: Evidence Report/Technology Assessment,” cited 5 studies that evaluate the association between a marker of health literacy and a marker of mental illness (Berkman et al., 2004). Four of these studies reported statistically significant associations between limited literacy and higher prevalence of depression, but not all of the associations remained significant in adjusted analyses. For example, Gazmarian et al. (2000) found that 13% of new Medicare recipients met criteria for depression on the Geriatric Depression Scale. | Introduction: study fills gap
Ginde AA | 2008 | Multicenter study of limited health literacy in emergency department patients | 1 | The Institute of Medicine and Agency for Healthcare Research and Quality have recently reported that 90 million adult Americans have difficulty comprehending and acting on medical information [1,2]. Patients with inadequate health literacy have limited knowledge of their chronic disease, poor medication adherence, and worse health outcomes. | Introduction: supports the problem statement
Drainoni ML | 2008 | Health literacy of HIV-positive individuals enrolled in an outreach intervention: results of a cross-site analysis. | None
Waite KR | 2008 | Literacy, social stigma, and HIV medication adherence | 5
Greene J | 2008 | Comprehension and choice of a consumer- directed health plan: an experimental study | None
Huizinga MM | 2008 | Low numeracy skills are associated with higher BMI | None
Wallace LS | 2008 | Relationship between health literacy and health-related quality of life among Tennesseans | 1 | One factor of particular importance was health literacy, which does not always correlate strongly with health literacy [4] Poor health literacy has been linked to poor general health status [4], but general health status is just one component of HRQOL. However, most studies of HRQOL have examined health status in specific populations, such as those with chronic disease, or targeted groups such as the elderly and Medicaid enrollees. We could find no published research, however, that studied the association of health literacy with overall HRQOL in adults of varying ages. To address this gap, we studied the relationship between health literacy and HRQOL in a sample of Tennessee adults obtaining healthcare at a university- based family medicine clinic. | Introduction: study fills gap
Cavanaugh K | 2008 | Association of numeracy and diabetes control | 3, 4 | 3: We did not find a statistically significant association between literacy or general numeracy and hemoglobin A1c, and other recent studies have also not found a significant correlation between literacy and hemoglobin A1c [19 –21]. One explanation may be that diabetes-related numeracy skills are more specific to diabetes self-management activities, and therefore are more strongly associated with hemoglobin A1c than are literacy or general numeracy. 4: We chose not to include education, literacy, and general numeracy skill level in our models because of high colinearity between these variables and DNT score and because of the potential for overadjustment [34]. We evaluated for interaction between DNT score and covariates, and this was not statistically significant.
Juzych MS | 2008 | Functional health literacy in patients with glaucoma in urban settings | None
Muir KW | 2008 | Health literacy and vision-related quality of life | None
Wright AJ | 2009 | The impact of numeracy on reactions to different graphic risk presentation formats: an experimental analogue study | None
Tang YH | 2008 | Health literacy, complication awareness, and diabetic control in patients with type 2 diabetes mellitus | None
Baker DW | 2008 | Health literacy, cognitive abilities, and mortality among elderly persons | None
Cho YI | 2008 | Effects of health literacy on health status and health service utilization amongst the elderly | 1 | As [Berkman et al. (2004)] has cautioned, potential confounders may lie in the causal pathway between health literacy and health outcomes. However, prior research tended to examine the consequences of low health literacy in a singular fashion and did not consider the inter-relationships among the various health outcomes (Lee, Arozullah, & Cho, 2004). In this study, we explored four potential intermediate factors that may link health literacy and health status and utilization: (1) disease knowledge, (2) health behavior, (3) preventive care, and (4) compliance. The relevance of these potential intermediary variables is reviewed below. | Introduction: study fills gap
White S | 2008 | Relationship of preventive health practices and health literacy: a national study | None
Wolf MS | 2007 | Patients' shame and attitudes toward discussing the results of literacy screening | 6 | The benefits of literacy screening are apparent, as it could lead to a proper allocation of health education and care management resources [DeWalt et al., 2004]. The risks are less clear however, identifying patients as having limited literacy may result in adverse consequences, such as concerns for social stigma and the avoidance of health services out of shame.
Nokes KM | 2007 | Health literacy and health outcomes in HIV seropositive persons | 1, 2 | Introduction: In the Agency for Healthcare Research and Quality (AHRQ) evidence-based report on health literacy, Berkman et al. [2004] reviewed 44 articles published as of May 2003 to examine whether health literacy skills were related to health outcomes, use of healthcare services, costs of healthcare, and disparities in health outcomes or healthcare service use, according to race, ethnicity, culture, or age. Variables associated with health outcomes included knowledge or comprehension, health behaviors, adherence, biochemical and biometric health outcomes, measures of disease prevalence, incidence, morbidity (including depression), and global health status measures. The AHRQ reviewers found that health literacy was related to knowledge and comprehension, hospitalization, global measures of health, and some chronic diseases, but the evidence was mixed, and findings were often dependent upon the analytic methods used. Methods: Health literacy is usually treated as a categorical variable [DeWalt, Berkman, Sheridan, Lohr, & Pignone, 2004]. | Introduction: lays out the state of the science Methods: justifies use of measure
von Wagner C | 2007 | Functional health literacy and health-promoting behaviour in a national sample of British adults | None
Peterson NB | 2007 | The influence of health literacy on colorectal cancer screening knowledge, beliefs and behavior | 2 | [Cited with the IOM report] More than 90 million Americans have poor literacy skills, and studies have suggested that low health literacy can be associated with less knowledge about cancer screening in general, less screening participation and worse clinical outcomes [17–19]. Little is known about how health literacy affects knowledge, attitudes and behaviors regarding CRC testing. | Introduction: supports problem statement
Osborn CY | 2007 | Health literacy: an overlooked factor in understanding HIV health disparities | | None
Aggarwal A | 2007 | The role of numeracy on cancer screening among urban women | 4 | Low health literacy has been found to correlate with less health knowledge, worse self management skills, less use of preventative tactics, higher rates of hospitalization, and death [15,16].Individuals with low literacy may find themselves unable to read prescription labels; health education materials; test results, appointment reminders; and other important, hut basic, documents. | Introduction: state of the science
Persell SD | 2007 | Limited health literacy is a barrier to medication reconciliation in ambulatory care | 2 | Methods: Patients are classified as having inadequate, marginal, or adequate health literacy skills. For this small study, we defined patients as having either inadequate health literacy or marginal/adequate health literacy. Although prior findings are mixed regarding associations between health outcomes and marginal health literacy, these individuals more often appear to be similar to those with adequate rather than inadequate literacy [16–18]. Discussion: Our finding that inadequate health literacy was associated with having two or more antihypertensive medications recorded in the medical record but not with the number of antihypertensive medications patients reported taking could indicate a relationship between inadequate health literacy and nonadherence in this population. Prior findings in HIV treatment found inconclusive results as to the relationship between health literacy and medication adherence. [10,13,18–20]. Yet HIV may differ from hypertension. Antiretroviral medications generally have a single manufacturer, and a prior study found that patients with limited literacy often rely on pill characteristics for identification | Methods: provides context for measure chosen Discussion: places findings in context
Jones M | 2007 | Oral health literacy among adult patients seeking dental care | 2 | Introduction: Patients with a low literacy level generally are 1.5 to three times more likely to experience poor outcomes in areas such as knowledge, intermediate disease markers, morbidity, general health status and use of health resources7]. Little research has been done on the role of literacy in oral health. Discussion: Although very little research has been undertaken in dentistry, ample justification exists for pursuing research in this area. Studies of medical care demonstrate the importance of health literacy in various health outcomes [1,7] and many peripheral studies show that those with low levels of education also tend to have poor dental behaviors and bad oral health outcomes [9]. | Introduction: problem statement Discussion: study fills gap
Walker D | 2007 | Patient education in rheumatoid arthritis: the effectiveness of the ARC booklet and the mind map | None
Hibbard JH | 2007 | Consumer competencies and the use of comparative quality information: it isn't just about literacy | None
Yin HS | 2007 | Association of low caregiver health literacy with reported use of nonstandardized dosing instruments and lack of knowledge of weight- based dosing | None
Baker DW | 2007 | Health literacy and mortality among elderly persons | 7
Laramee AS | 2007 | Relationship of literacy and heart failure in adults with diabetes | 2, 4 | Dewalt's systematic review concluded that people who read at low levels are 1.5 to 3 times more likely to have an adverse outcome compared to people who read at higher levels [17].. | Introduction: supports problem statement
Wolf MS | 2007 | To err is human: patient misinterpretations of prescription drug label instructions | | None
Campbell MJ | 2007 | Developing a parsimonious model for predicting completion of advance directives | None
Bennett IM | 2007 | Literacy and depressive symptomatology among pregnant Latinas with limited English proficiency. Am J Orthopsychiatry | 1 | The standard designations of inadequate and marginal literacy levels were selected for the current analysis because they have been associated with increased risk of poor health outcomes [Baker, Parker, Williams, & Clark, 1998; Berkman et al., 2004; Kalichman et al., 1999; Schillinger et al., 2002; Williams, Baker, Honig, Lee, & Nowlan, 1998; Williams, Baker, Parker, & Nurss, 1998]. Owing to ceiling effects, this instrument is used with ordered categorical rather than continuous outcomes for analyses. | Methods: justification of measure
Schillinger D | 2008 | Seeing in 3-D: examining the reach of diabetes self- management support strategies in a public health care system | 7 | Although efficacy studies have demonstrated the benefit of a range of SMS strategies— even among selected vulnerable populations [Dewalt et al., 2006; Philis-Tsimikas et al., 2004; Rothman et al., 2004]—there is little translational research on SMS implementation to guide health system planners and little research on the reach of such programs with respect to diverse clinics, providers, and populations in safety net systems (Eakin et al., 2002; Lemon, Zapka, Estabrook, & Benjamin, 2006).
Murray MD | 2007 | Pharmacist intervention to improve medication adherence in heart failure: a randomized trial | 7 | Although some programs involved a pharmacist [51– 53], we are unaware of any that were managed from a pharmacy by a pharmacist who dispensed medications and provided other helpful functions.
Mayben JK | 2007 | Predictors of delayed HIV diagnosis in a recently diagnosed cohort. AIDS Patient Care STDS | 2, 4 | According to the National Adult Literacy Survey of over 26,000 adults, approximately 40–44 million (21%–23%) adults in the United States were functionally illiterate, and an additional 50 million (25%–28%) adults were marginally literate [6]. Minorities, older adults, and those with less than a high school education tended to perform in the lower literacy levels [6]. Low literacy has been associated with poorer health outcomes [7]. Health literacy is a type of literacy that has been defined as “the degree to which individuals have the capacity to obtain, process and understand basic health information and services for appropriate health decisions” [8]. | Introduction: supports problem statement
Peters E | 2007 | Less is more in presenting quality information to consumers | None
Miller DP | 2007 | The effect of health literacy on knowledge and receipt of colorectal cancer screening: a survey study | None
Mayhorn CB | 2007 | Refining teratogen warning symbols for diverse populations | None
Kripalai S | 2007 | Development of an illustrated medication schedule as a low- literacy patient education tool | 2, 5 | The effects of low health literacy extend to many other areas of healthcare, contributing to disparities in disease-related knowledge, self-care activities, and health outcomes [21, 22]. Low- literacy patients demonstrate greater utilization of acute care services, incur significantly higher health care costs, and have higher mortality rates [23–26]. | Introduction: supports problem statement
Powell CK | 2007 | The relationship between health literacy and diabetes knowledge and readiness to take health actions | 2 | Methods: For each of the 3 models, the covariates chosen for analysis were those found to be significant at the .10 level in bivariable analyses or reported to be significantly associated with diabetes outcomes in previous published work on health literacy [3,13,20]. Most recent hemoglobin A1C level, chosen to represent the patient’s current level of glycemic control, required log base 10 transformation to induce approximate normality. Results: Years with diabetes was initially considered for inclusion in the model based on prior research [3,13,20]; however, the model lost significance with the addition of the covariate (P □□ .06 ), with no impact on fit (R2 remained 0.27). However, suspected that these patients would be less likely than the general population to be ready to care for their disease given the number of perceived barriers they must overcome to receive adequate medical care. Also, the recent systematic review from DeWalt et al. states that one of the key aspects to determining the true relationship between literacy and health is the analysis of confounders. If the appropriate confounders are not included in the model, the significance of the relationship may be inaccurate. | Methods: justification of measures Results: justification of measures Conclusions: places study findings in context
Sanders LM | 2007 | Caregiver health literacy and the use of child health services | None
Wolf MS | 2007 | Health literacy and health risk behaviors among older adults | 1, 2 | 1: In 2004, the Agency for Healthcare Research and Quality released a systematic review of the literature on health literacy and its relationship to healthcare use and outcomes [13]. This report issued a call for further research to document more consistently the causal pathways through which health literacy affects individual health. One particular mechanism that has been previously proposed is through various health risk behaviors known to be linked to health status and outcomes, despite the lack of empirical evidence to support such a pathway 2: One particular mechanism that has been previously proposed is through various health risk behaviors known to be linked to health status and outcomes, despite the lack of empirical evidence to support such a pathway [14,15] Although prior studies have documented an association between lower educational attainment and higher prevalence of health risk behaviors (i.e., cigarette smoking, alcohol consumption, physical activity, and body mass index [BMI]), [16–18]. | Introduction: study fills gap
Davis TC | 2006 | Literacy and misunderstanding prescription drug labels | None
Wolf MS | 2007 | Literacy, self-efficacy, and HIV medication adherence | 2, 6 | Based on prior studies examining the relationship between literacy and health outcomes [22], and common proposed pathways for how literacy might impact HIV medication adherence [23], we hypothesized that limited literacy would directly influence both patients’ knowledge of their treatment regimen and self-efficacy to properly manage medication schedules. Our research also supports previous speculations that the relationship between literacy and health outcomes, including medication adherence, is not linear [37– 40]. Rather, there may be a threshold effect where low literacy, at the 6th grade level and below, poses a substantial problem on adherence to antiretroviral regimens. | Introduction: basis for hypotheses
Gazmararian JA | 2006 | Factors associated with medication refill adherence in cardiovascular-related diseases: a focus on health literacy | 9 | It would be expected that an adequate level of functional health literacy is essential for understanding and processing messages that generate the motivation, beliefs, and behaviors to achieve successful medication adherence [32]. It is likely that inadequate health literacy skills are related to impaired comprehension of medical care instructions, and as a consequence, reduced medication adherence [33]. The 3 published studies that have directly examined this relationship found inconsistent results. Kalichman et al. [27] noted an association between health literacy and self- reported adherence to antiretroviral agents, while Golin et al. [34]. | Introduction: state of the science
Graham J | 2007 | Medication beliefs as mediators of the health literacy- antiretroviral adherence relationship in HIV- infected individuals | 1 | In general, patients with low literacy have less knowledge of the management and treatmenet of their own chronic diseases and have poorer diseas outcomes [Berkman et al, 2004; Estrada, Martin-Hryniewicz, Peek, Collins, and Byrd, 2004; Hope, Wu, Tu, Young and Murray, 2004; Schillingger et al, 2002; Wilson, Tchetgen, and Speigelman, 2001]. | Introduction: statement of problem
Morrow D | 2006 | Correlates of health literacy in patients with chronic heart failure | 2 | Approximately half of the adults in the United States have inadequate or marginal functional health-related literacy, which challenges their ability to navigate the health care system. Lower health literacy is associated with poorer health status, less health care knowledge, poorer self-care abilities (e.g., medication adherence), reduced use of preventive services, and increased hospitalization and health care costs [Ad Hoc Committee, 1999; DeWalt, Berkman, Sheridan, Lohr, & Pignone, 2004; Nielsen- Bohlman, Panzer, & Kindig, 2004]. Thus, it is important to identify people with less than adequate health literacy and determine the reasons why this is so. We investigated health literacy among middleaged and older adults with chronic heart failure (CHF) Such a model would help explain associations between health literacy and demographic variables such as age and race, which researchers have investigated because of their interest in health literacy as a mediator of differences in health care outcomes related to socioeconomic status [Ad Hoc Committee, 1999; DeWalt et al., 2004]. The model would also guide development of strategies for mitigating effects of low literacy on health behaviors and outcomes. We plan to investigate whether relationships between health literacy and adherence are mediated by differences in cognitive abilities and whether these relationships also mediate the impact of demographic variables on adherence and health outcomes. Such findings would be consistent with functional definitions that view health literacy in terms of how individuals’ skills match the demands of specific | Introduction: supports problem statement
Rothman RL | 2006 | Patient understanding of food labels: the role of literacy and numeracy | 2, 9 | Discussion: In multivariable analyses lower literacy status and numeracy status remained significantly associated with poorer understanding of nutrition labels even after adjusting for income, education, and other factors. Previous studies have demonstrated that patients with poor literacy skills have worse knowledge of their chronic illness and can have worse clinical outcomes [15,17,32]. Providers need to be careful, for example, about asking a patient with heart failure or hypertension to limit their sodium intake to 2 g if the patient cannot accurately interpret food labels. Speaking clearly and concisely, avoiding jargon, setting realistic goals, and using low-literacy— oriented materials can aid patient comprehension [32, 35–42]. | Discussion: places findings in context [DeWalt and Pignone peer reviewed]
Rutherford J | 2006 | Low literacy: a hidden problem in family planning clinics | None
Vavrus F | 2006 | Girls' schooling in Tanzania: the key to HIV/AIDS prevention? AIDS Care | None
Yates K | 2006 | Comprehension of discharge information for minor head injury: a randomised controlled trial in New Zealand | None
Morris NS | 2006 | Literacy and health outcomes: a cross- sectional study in 1002 adults with diabetes | 2, 9 | Introduction: Evidence is beginning to accumulate about the prevalence of limited health literacy and its association with the use of health care services [5–7,10–13] and health outcomes [8,14–16]. Discussion: Another possible explanation for our finding of a lack of a significant association between literacy and health outcomes is that optimal self- management of diabetes may not be solely dependent on reading ability. In addition to print literacy, health literacy includes numeracy, oral literacy, culture and context [2]. The published literature on “health literacy” typically reports measures of reading ability and rarely, if ever, addresses the broader domains of health communication [14,31,32]. While there may be great value in assessing health literacy to address communication barriers between patients and health care providers, we still do not know what aspects of health literacy | Introduction: state of the science Discussion: placing findings in context
Sudore RL | 2006 | Use of a modified informed consent process among vulnerable patients: a descriptive study | None
Sentell TL | 2006 | Importance of adult literacy in understanding health disparities | None
Howard DH | 2006 | Impact of health literacy on socioeconomic and racial differences in health in an elderly population | 2 | Despite the intuitive connection between low health literacy and disparities, a recent review of the literature on health literacy [2] found only 1 study [3] documenting the link statistically. In this study, we used one of the only large datasets containing measures of health literacy, demographic characteristics, and health outcomes to explore the impact of health literacy on differences in health status and vaccination by educational attainment and race. | Introduction: study fills gap
Fang MC | 20206 | Health literacy and anticoagulation- related outcomes among patients taking warfarin | 2 | Limited health literacy is prevalent in certain populations in the United States, such as the elderly,[2,3] and is associated with receiving fewer preventive services, difficulty following medication instructions, and in some studies, with poorer health outcomes [4–10]. Health literacy may be of particular importance under conditions that involve substantial patient-provider discussion of risks and benefits and in those requiring complex management. One such therapy is anticoagulation with warfarin. | Introduction: supports the problem statement
Paasche-Orlow MK | 2006 | Health literacy, antiretroviral adherence, and HIV- RNA suppression: a longitudinal perspective | 2 | Introduction: Health literacy has emerged as a cross-cutting priority to improve the quality of health and health care in America.1–4 Medical and public health literature highlight the high reading demands made on people who are often in need of important health information.5 In addition, there is a growing body of literature indicating that people with limited health literacy have worse health status [6,7]. Discussion: Fourth, health literacy was defined by the 66-word REALM, which is merely a word pronunciation test. While the REALM is the most commonly used tool to measure literacy in the medical literature and correlates well with other established health literacy and basic literacy instruments (r=.84 to .97), a more comprehensive test of health literacy might have provided different results [4,7]. | Introduction: supports problem statement Discussion: places findings in context
Lindau ST | 2006 | Health literacy as a predictor of follow-up after an abnormal Pap smear: a prospective study | 1 | This study adds to a growing number of investigations that implicate low literacy as a correlate of negative health behaviors 7,8 and a cause of poor health outcomes [9–10]. In the context of general medical care, it has been suggested that literacy testing should and can occur routinely in the clinic [11–13]. | Discussion: places findings in context
Weiss BD | 2006 | Literacy education as treatment for depression in patients with limited literacy and depression: a randomized controlled trial | 1 | Research has demonstrated that limited literacy is associated with poorer health outcomes and lower health status [5–9]. But, as pointed out in a report on health literacy from the Agency for Healthcare Quality and Research [10], there is little evidence that improving literacy skills can improve an individual’s health. Indeed, to our knowledge, no research in an industrialized nation has ever demonstrated that enhancing literacy skills can actually cause someone to “get better” from an illness or chronic condition. The study reported here is a preliminary investigation of whether improving literacy skills can improve a specific health outcome—severity of depression—in a cohort of depressed individuals with limited literacy skills in the United States. | Introduction: state of the science; study fills gap
Lincoln A | 2006 | Impact of health literacy on depressive symptoms and mental health-related: quality of life among adults with addiction | 1,2 | Introduction Approximately 90 million American adults have low health literacy and lack the basic literacy skills to function in society.1–3 A growing body of work exists linking low literacy with an array of negative outcomes [4]. These outcomes include more frequent hospitalization,5,6 higher rates of health services utilization, and worse prevention practices in people with diabetes,7,8 asthma,9,10 cancer,11–13 and other chronic illnesses.14,15 Discussion The recent AHRQ evidence review, “Literacy and Health Outcomes: Evidence Report/Technology Assessment” [23] cites 5 studies that evaluate the association between a marker of health literacy and a marker of mental illness. Four of these studies report statistically significant associations between low literacy and higher prevalence of depression; however, not all of these associations remained significant in adjusted analyses. Each of these studies and more recent work by Wolf et al. [24] have relied on cross-sectional analyses, and thus do not allow for consideration of causal inferences. For example, Gazmarian et al. 2000 [25] found that 13% of new Medicare recipients had depression according to the geriatric depression scale. Subjects with low health literacy were 3 times more likely to have depression. However, after controlling for demographics, social support, health behavior, and health status, health literacy did not remain an independent risk factor for depressive symptoms. | Introduction: state of the science Discussion: places findings in context
Mancuso CA | 2006 | Impact of health literacy on longitudinal asthma outcomes | 2, 4 | The term health literacy has been used to describe the ability to read and comprehend medical information [1]. Such skills may impact all aspects of medical care. In particular, multiple studies carried out in different countries provide evidence that patients with less health literacy have worse health outcomes [2,3]. Some of the main outcomes considered were resource utilization and markers of disease control [4,5]. | Introduction: supports problem statement
Sudore RL | 2006 | Limited literacy and mortality in the elderly: the health, aging, and body composition study | 7 | Finally, given the mismatch between the high literacy demands of the health care system and the limited literacy capacities of many older individuals [50] limited literacy may impede access to health care and/or effective chronic disease management. Health care systems may be poorly designed to meet the needs of persons with limited literacy, thereby contributing to literacy-related disparities. Two trials that evaluated the effect of re-engineering health care delivery to lower literacy demands demonstrated improvements in outcomes among those with lower literacy [52,53].
Muir KW | 2006 | Health literacy and adherence to glaucoma therapy | None
Sudore RL | 2006 | Limited literacy in older people and disparities in health and healthcare access | 7 | Additional research should be conducted to identify creative and multidisciplinary interventions to help older people with limited health literacy access the healthcare system to obtain the services they need. Interventions will likely need to combine multidisciplinary case management approaches that have been successful in geriatric [47,48] and low-literacy populations [49,50].
Haggstrom DA | 2006 | Black-white differences in risk perceptions of breast cancer survival and screening mammography benefit | None
Schillinger D | 2006 | Does literacy mediate the relationship between education and health outcomes? A study of a low-income population with diabetes | 4, 8 | 4: “Health literacy” has been defined as a measure of an individuals’ ability to perform basic reading and numerical tasks required to optimally function in the health care environment,18 and more broadly as the degree to which individuals have the capacity to obtain, process, and understand basic health information and services needed to make appropriate health decisions.9,19 Current measures of health literacy are highly correlated with standard measures of general literacy [20–22]. 8: A small body of evidence suggests that such approaches could reduce or even eliminate education- and literacy-related disparities in the chronic disease context [33,34,78,79].
Raehl CL | 2006 | Screening tests for intended medication adherence among the elderly | None
Sarkar U | 2006 | Is self-efficacy associated with diabetes self- management across race/ethnicity and health literacy? | 1 | Within this patient population, individuals with limited health literacy may be especially vulnerable to these experiences. A growing body of research demonstrates that limited health literacy, a prevalent problem in vulnerable populations, is independently associated with poor self- rated health [23,24], higher utilization of services [25–28], fewer preventive services [29,30], and worse glycemic control and more diabetes complications [31]. Therefore, self-efficacy may be a relevant determinant of self management behaviors among populations with limited health literacy [32–35]. We sought to determine whether diabetes self-efficacy was associated with recommended self-management behaviors in an urban, diverse population with a high prevalence of limited health literacy. | Introduction: state of the science
Mancuso CA | 2006 | Asthma patients’ assessments of health care and medical decision making: the role of health literacy | 2 | Introduction: Most recent investigations focusing on health literacy have considered its impact on knowledge of disease, outcomes of disease, and resource utilization [3–6]. Few studies have considered health literacy and patients’ experiences with health care [7]. In addition, it is not known whether literacy affects patients’ desires to be informed of their treatment options and to participate in making decisions about their care. Discussion: To our knowledge, this is the first study to assess the association between health literacy and medical decision making in asthma patients. This result provides additional incentive to physicians to find better ways to explain treatments to patients and to encourage them to collaborate in their care. These are critical issues for asthma because self-management is a determinant of outcome [6]. | Introduction: state of the science Discussion: placing findings in context
Kalichman SC | 2005 | Nurse-delivered antiretroviral treatment adherence intervention for people with low literacy skills and living with HIV/AIDS | None
Seligman HK | 2005 | Physician notification of their diabetes patients’ limited health literacy. A randomized, controlled trial | 1 | Both the Institute of Medicine1 and the Agency for Healthcare Research and Quality [5] have recently released reports highlighting the clinical significance of limited HL. When compared to patients with adequate HL, patients with limited HL demonstrate lower knowledge of chronic disease prevention and management [6–12] worse health status7,13,14 and higher utilization of hospital and emergency room services [15,16]. The relationship between limited HL and poorer health outcomes, particularly among patients with chronic disease, may be mediated by sub-optimal physician-patient communication and patient self-management skills [2,6,9,17,18]. Discussion: The increased attention to HL1, [5] and the evolution of shorter screening instruments25,27,28 has increased interest in developing screening programs in the clinical context. This trial suggests we exercise caution before implementing such programs. | Introduction: supports problem statement Discussion: places findings in context
van Servellen G | 2005 | Effects of a treatment adherence enhancement program on health literacy, patient-provider relationships, and adherence to HAART among low-income HIV-positive Spanish-speaking Latinos | None
Guerra CE | 2005 | Literacy and knowledge, attitudes, and behavior about colorectal cancer screening | None
Roth MT | 2005 | Self-reported medication use in community-residing older adults: A pilot study | None
Wolf MS | 2005 | Health literacy and functional health status among older adults | 1, 2 | Introduction: These cumulative findings have led to groundbreaking responses by national organizations and federal agencies [13,15–17]. The Agency for Healthcare Research and Quality, in a recently released report, calls for further research that more consistently and clearly documents the relationship between health literacy and health status and outcomes [17]. The Agency for Healthcare Research and Quality report raises important questions about the characterization of the relationship between literacy and personal health. Although the body of literature has grown considerably within the past several years, few research studies11,18 have been published that directly link health literacy to the health status of individuals. The objective of this study was to investigate the relationship between health literacy and functional health status among a cohort of new Medicare managed care enrollees from 4 US cities. Discussion: Our finding that inadequate health literacy is independently associated with worse health is consistent with the results of previous cross-sectional studies [11,18, 28, 29] of highly selected patient populations. Because our study was population based, it should be less subject to selection bias than previous studies that enrolled people at the time they were seeking medical care. | Introduction: study fills gap Discussion: places findings in context
Paasche- Orlow MK | 2005 | Tailored education may reduce health literacy disparities in asthma self-management | 1, 2, 8 | Health literacy is “the degree to which individuals have the capacity to obtain, process, and understand basic health information and services needed to make appropriate health decisions” [1–4] and is most often measured by reading comprehension of health-related information [5–6]. Multiple studies indicate that inadequate health literacy is associated with worse health status and higher rates of hospitalization across a number of patient populations [4, 7, 8], including patients with diabetes mellitus, patients with HIV infection, and the elderly [9–12]. In cross-sectional studies, inadequate health literacy has been linked to lower asthma-related knowledge [14, 15] and improper use of metered dose inhalers (MDIs) [14]. Although national asthma guidelines recommend patient education to improve patient–physician partnerships for care [16], no studies have evaluated the extent to which inadequate health literacy serves as a barrier for patients to learn and retain asthma self-management skills [17]. The objective of this study was to examine the relationship between inadequate health literacy and difficulties learning and retaining instructions about discharge medications and appropriate MDI technique. | Introduction: state of the science; study fills gap
Johnston MV | 2005 | Health literacy, morbidity, and quality of life among individuals with spinal cord injury | None
Gerber BS | 2005 | Implementation and evaluation of a low-literacy diabetes education computer multimedia application | 1 | There is a growing awareness of the impact of low health literacy on diabetes [1, 2]. Low health literacy poses a major barrier to education and self-management [3]. Health literacy directly impacts health outcomes, such as hospitalization risk, particularly in those with chronic diseases [4,5]. | Introduction: problem statement; state of the science
Barragan M | 2005 | Low health literacy is associated with HIV test acceptance | 1 | Low health literacy is associated with poor understanding of written or spoken medical advice and may negatively impact the health of the population [4,6] Patients with inadequate health literacy have a complex variety of communication difficulties that limit their ability to read and understand ducational brochures, appointment slips, informed consent documents, and labels on pill bottles.1 Not surprisingly, patients who have inadequate health literacy who are also HIV infected are less likely to know and understand essential information about their medical condition, [6,7] similar to patients with other chronic diseases such as hypertension, diabetes, and asthma [3–5,8–10]. HIV-infected patients with low health literacy appear to be four times more likely to be non-adherent with their antiretroviral medications than patients with adequate literacy [11], and programs designed to enhance health literacy promote adherence to therapy.12 Furthermore, better health literacy correlates with improved outcomes among HIV- infected patients [6,13,14] However, the full impact of patients’ health literacy on HIV/AIDS has not been widely explored.7 Certain groups have an especially high prevalence of low literacy. They include people who have completed fewer years of education, persons of certain racial or ethnic groups, the elderly, and persons with lower cognitive ability [6]. Discussion Previous studies have found that individuals with low health literacy are less likely than individuals with adequate literacy to know essential information about their health, [1–6] to have poorer health outcomes, and increased hospitalization rates [6,17,18]. | Introduction: supports problem statement Discussion: places findings in context
Hwang SW | 2005 | The effect of illustrations on patient comprehension of medication instruction labels | None
Howard DH | 2005 | The impact of low health literacy on the medical costs of Medicare managed care enrollees | 1 | Recently released reports by the Institute of Medicine and Agency for Healthcare Research and Quality conclude that the 90 million adults in our country with limited health literacy cannot fully benefit from medical care and the health care system [4,27]. The reports note various interventions that hold promise for improving health literacy in various clinical settings. We have elected to present the more conservative set of results based on modelsthat include controls for education and comorbid conditions, but, as stated above, these may lead to estimates that are biased downwards. As noted by Berkman et al. [27], “One limitation of the knowledge base to date is lack of appropriate specification for analytic models when variables being considered as potential confounders actually medicate the effect of reading ability on important health outcomes.” With further refinements to the concept of “health literacy,” it may be possible to narrow down the list of potential confounders for future cost studies. | Discussion: context for findings; support research recommendations
Guerra CE | 2005 | Literacy and knowledge, attitudes and behavior about mammography in Latinas | None
Ferreira MR | 2005 | Health care provider- directed intervention to increase colorectal cancer screening among veterans: results of a randomized controlled trial | None
Garbers S | 2004 | Inadequate functional health literacy in Spanish as a barrier to cervical cancer screening among immigrant Latinas in New York City | 1 | Health literacy has been defined as “the degree to which individuals have the capacity to obtain, process, and understand basic health information and services needed to make appropriate health decisions” [1]. Improving health literacy has been added as a Healthy People 2010 objective [2], and two recent reports by the Institute of Medicine and the Agency for Healthcare Research and Quality summarize the data regarding the prevalence of low health literacy and its relationship to health care quality, use, outcomes, and disparities [3, 4]. Despite these findings, health care providers are often unaware of the health literacy skills of their patients [5–7]. | Introduction: state of the science; problem statement
Kim S | 2004 | Association of health literacy with self- management behavior in patients with diabetes | None (pre report)
Wolf MS | 2004 | Health literacy and patient knowledge in a Southern US HIV clinic | None (pre report)
Chew LD | 2004 | The impact of low health literacy on surgical practice | None (pre report)
Estrada CA | 2004 | Literacy and numeracy skills and anticoagulation control | None (pre report)
Rothman R | 2004 | The relationship between literacy and glycemic control in a diabetes disease- management program | None (pre report) | | DeWalt is a coauthor
Davids SL | 2004 | Predictors of pessimistic breast cancer risk perceptions in a primary care population | None (pre report)
Baker DW | 2004 | Health literacy and use of outpatient physician services by Medicare managed care enrollees | None (pre report)
Kleinpeter MA | 2003 | Health literacy affects peritoneal dialysis performance and outcomes | None (pre report)
Endres LK | 2004 | Health literacy and pregnancy preparedness in pregestational diabetes | None (pre report)
van Servellen G | 2003 | Program to enhance health literacy and treatment adherence in low-income HIV- infected Latino men and women | None (pre report)
Smith JL | 2003 | Literacy in primary care populations: is it a problem? | None (pre report)
Coyne CA | 2003 | Randomized, controlled trial of an easy-to-read informed consent statement for clinical trial participation: a study of the Eastern Cooperative Oncology Group | None (pre report)
Sheridan SL | 2002 | Numeracy and the medical student’s ability to interpret data | None (pre report)
Schwartz LM | 1997 | The role of numeracy in understanding the benefit of screening mammography | None (pre report)
Conwell LS | 2003 | Early adolescent smoking and a web of personal and social disadvantage | None (pre report)
Sentell TL | 2003 | Low literacy and mental illness in a nationally representative sample | None (pre report)
Campbell FA | 2004 | The effect of format modifications and reading comprehension on recall of informed consent information by low-income parents: a comparison of print, video, and computer- based presentations | None (pre report)
DeWalt DA | 2004 | Development and pilot testing of a disease management program for low literacy patients with heart failure | None (pre report)
Hope CJ | 2004 | Association of medication adherence, knowledge, and skills with emergency department visits by adults 50 years or older with congestive heart failure | None (pre report)
LeVine RA | 2004 | Maternal literacy and health behavior: a Nepalese case study | None (pre report)
Rothman RL | 2004 | Influence of patient literacy on the effectiveness of a primary care-based diabetes disease management program | 1 | No published studies have rigorously examined interventions that can mitigate literacy-related disparities in patients with diabetes [14]. We previously conducted a pilot study that suggested that a comprehensive intervention might improve glycemic control for patients with low literacy [15] but that study lacked a control group. To better examine this issue, we recently completed a randomized controlled trial of a comprehensive disease management program that included strategies to overcome clinician deficits and patient barriers, including low literacy, for patients with diabetes and poor glycemic control. This program successfully improved blood pressure and glycemic control [16]. This article examines how patient literacy influenced the effectiveness of this program. | Introduction: study fills gap Coauthored by DeWalt
Weiss BD | 2004 | Relationship between health care costs and very low literacy skills in a medically needy and indigent Medicaid population | None (pre report)
Bosworth HB | 2005 | Nurse administered telephone intervention for blood pressure control: a patient- tailored multifactorial intervention | None
Paasche- Orlow MK | 2005 | Educational attainment but not literacy is associated with HIV risk behavior among incarcerated women | 2 | Introduction: Low educational attainment and low literacy have been linked to low levels of knowledge and worse health outcomes for such chronic diseases as diabetes, asthma, and HIV infection [30–35]. However, the relationship of educational attainment and literacy with HIV risk behavior has not been evaluated. We sought to examine the relationship between educational factors and HIV risk behavior among women in short-term incarceration. In addition, we sought to provide an estimate of the independent relationship of specific educational factors and HIV risk behavior in an adjusted analysis. Discussion: The mechanisms by which this association is elaborated are likely complex and include such factors as life course social stratification that clusters types of experiences over an individual’s lifetime, biological factors that predispose people both to education and health advantages, and social dynamics that involve the broader cultural, economic, policy, and political environment [43]. Similar mechanisms have been evoked to explain the connection between literacy and health, [35,44] but specific delineation of risk factors and mechanisms for crucial health conditions, such as HIV, may help inform the development and implementation of successful interventions. | Introduction: study fills gap Discussion: placing findings in context
Arozullah AM | 2006 | The roles of low literacy and social support in predicting the preventability of hospital admission | None
Bennett I | 2006 | Breaking it down’: patient-clinician communication and prenatal care among African American women of low and higher literacy | 1 | We were surprised that literacy was not associated with prenatal care utilization. The adherence to medical care by patients with chronic diseases has been shown to vary by literacy [24]. The women in this sample all had very high rates of poor prenatal care, and it may be that the risk associated with low literacy is not distinguishable in that context. We were intrigued by the finding that communication with clinicians was an important theme for all of the participants in this study. | Discussion: placing findings in context
Carbone ET | 2006 | Testing the feasibility of an interactive learning styles measure for U.S. Latino adults with type 2 diabetes and low literacy | None
DeWalt DA | 2006 | A heart failure self- management program for patients of all literacy levels: a randomized, controlled trial [ISRCTN11535170] | 2, 6 | Limited literacy skills are common among adults in the United States [1]. Low literacy is associated with increased risk of hospitalization and worse control of chronic diseases [1–4]. Heart failure is a common chronic illness requiring multiple medications and significant self-care. Heart failure is the leading cause of hospitalization in the Medicare population [5]. The complexity of care for heart failure puts people with low literacy at considerable risk for adverse outcomes including hospitalization, worse quality of life, and mortality. | Introduction: supports problem statement DeWalt is a co- author
Ives TJ | 2006 | Predictors of opioid misuse in patients with chronic pain: a prospective cohort study | None | | DeWalt was a co- author
Kripalani S | 2006 | Predictors of medication self- management skill in a low-literacy population. J Gen Intern Med | 4 | Two alternate modeling strategies were also performed. In one, years of schooling was excluded from the list of potential predictors. Some note that education is causally associated with literacy and that controlling for education may therefore constitute over adjustment and falsely attenuate the observed effect between literacy and the outcome of interest [20]. The second alternate approach treated continuous covariates as such, to ensure that categorization of these predictors had no meaningful effect on the observed association between literacy and MMC.
Wolf MS | 2006 | A critical review of FDA-approved Medication Guides | None
Wolf MS | 2006 | Literacy, race, and PSA level among low- income men newly diagnosed with prostate cancer | None
Brock TP | 2007 | Using digital videos displayed on personal digital assistants (PDAs) to enhance patient education in clinical settings | None
DeWalt DA | 2007 | Literacy and its relationship with self- efficacy, trust, and participation in medical decision making | 2, 9 | Research over the past decade has demonstrated an association between literacy and health-related knowledge, self-management behaviors, self-reported health, rates of hospitalization, and control of diabetes [1]. However, research to date has not elucidated the factors that mediate the relationship between low literacy and worse health outcomes [1,2] Finding a relationship between literacy and health implies that an in ability to acquire and understand health related information is an important mediating factor for determining good outcomes. Thus, many interventions have sought to improve readability of written materials, use other media altogether, or enlist additional clinical personnel to educate patients [3]. Further, no study demonstrates that enhancing the readability of health information alone improves health outcomes [3]. | Introduction: state of the science DeWalt is co-author
DeWalt DA | 2007 | Low parental literacy is associated with worse asthma care measures in children | 2, 4 | Low literacy is associated with a range of adverse health outcomes in adults including self reported health status, diabetes control, HIV viral load, rate of all-cause hospitalization, and all-cause mortality [8, 9]. Additionally, low literacy is associated with several other markers of vulnerability including non- white race and low socioeconomic status (SES). 10 Many researchers have hypothesized that low literacy may be a contributing factor in disparities according to race or SES, although this research is just emerging [11–13]. | Introduction: supports problem statement
Hahn EA | 2007 | The impact of literacy on health-related quality of life measurement and outcomes in cancer outpatients | 1, 2, 4 | 2: Introduction: Evidence about the relationship between literacy and patient-reported outcomes such as HRQL and perceived health status is limited. A systematic review by DeWalt and colleagues identified only four high- quality studies that evaluated this relationship [15]. These were conducted with adult education students [16], patients with Type-2 diabetes [17], patients presenting to the emergency department or ambulatory clinic [18], and Medicare managed care patients [19]. Additional analyses were recently published for the Medicare patients [20]. Four studies found an association between poorer reading ability and poorer HRQL/ perceived health status [16, 18–20], while the fifth did not [17]. Furthermore, two of these studies used only a single global health item and all used interviewers to gather self-report data. Research is needed to better clarify the relationship between literacy and patient- reported health outcomes. Prerequisites for this research are the development and validation of measurement techniques for low literacy populations, and validation of measures to ensure that differences in reported health between literacy groups do not reflect underlying measurement bias [15, 18]. The purpose of this study was to address all of these research needs. 1: Discussion: Recent studies have reported that low literacy is associated with health disparities such as reduced access to health information, poorer understanding of illness and treatment, less effective disease management, less understanding and use of preventive services, poorer physiological health markers, lower medication adherence, increased hospitalizations and higher financial costs [18, 61, 64–68]. However, little has been known about the association between literacy and HRQL/health status. The results of this study suggest that low literacy is not an independent risk factor for poorer HRQL outcomes. | Introduction: study fills gap Discussion: places findings in context
Murray MD | 2009 | Factors associated with exacerbation of heart failure include treatment adherence and health literacy skills | 2 | However, until recently, socioeconomic and biomedical factors have seldom been simultaneously assessed [9,10]. In addition, assessments of treatment adherence and health literacy skills are rarely considered in any analysis, even though these patient abilities are essential for effective self- management of chronic illness and are important for improved health outcomes [11–13]. Guided by a framework that links the health system and patient characteristics to self-care and health outcomes [14], we measured a comprehensive set of variables in a cohort of 192 participants nested within a randomized controlled trial to ascertain patient characteristics and risk factors associated with clinical deterioration requiring emergency department visits or hospitalization. | Introduction: study fills gap
Kripalai S | 2007 | Low-literacy interventions to promote discussion of prostate cancer: a randomized controlled trial | None
Sudore RL | 2007 | An advance directive redesigned to meet the literacy level of most adults: a randomized trial | None
Davis TC | 2008 | Provider and patient intervention to improve weight loss: a pilot study in a public hospital clinic | 2 | Health literacy in its simplest terms refers to one’s ability to understand and act on health information [6]. Research suggests that an individual’s general literacy skills will likely influence his or her health literacy abilities [6,11,12]. Recent studies of obese patients in a public hospital found that those with low literacy skills had significantly less knowledge about weight loss and its health implications, poorer attitudes, and more negative behaviors [13,14]. | Introduction: state of the science
Kripalani S | 2008 | Clinical research in low-literacy populations: using teach-back to assess comprehension of informed consent and privacy information | None
Powers BJ | 2008 | Literacy and blood pressure--do healthcare systems influence this relationship? A cross- sectional study | 2, 7 | Introduction: Over 90 million adult Americans lack the literacy skills to effectively function in the current healthcare environment [1] – a number that has not changed significantly in the past 10 years [2]. Low health literacy is found in many different healthcare settings [3,4] and is most common in older patients, those with lower education levels, immigrants, and racial minorities [5]. Prior research has supported the association between literacy and disease knowledge, utilization of preventative services, hospitalization, overall health status, chronic disease control, and mortality in elderly adults [6–8]. Due to a growing body of evidence regarding these associations, literacy has been deemed a national priority [1,9,10]. Discussion: Although we adjusted for several patient variables that may be associated with systolic blood pressure, we did not include measures of patient knowledge, health beliefs, or health status, which have previously been associated with literacy and may differ between the two patient populations [6,7]. In addition to patient characteristics, we did not explore other variables that may mediate our findings such as type of health insurance coverage or more specific clinic site level differences in how care is delivered. | Introduction: state of the science Discussion: places findings in context
Robinson LD | 2008 | The impact of literacy enhancement on asthma-related outcomes among underserved children | 2 | Studies conducted in low- income urban populations have documented that low literacy is a predictor of poor health outcomes, even after other sociodemographic variables are considered [24–26]. Other studies have also reinforced the concept that literacy is vital to health- related outcomes [24,25,27–29]. To the best of our knowledge, there have not been any asthma-related interventions which have evaluated the relationship between literacy and health by improving both areas simultaneously. | Introduction: state of the science
Sudore RL | 2008 | Engagement in multiple steps of the advance care planning process: a descriptive study of diverse older adults | None
Waldrop- Valverde D | 2008 | The effects of low literacy and cognitive impairment on medication adherence in HIV-positive injecting drug users | 1, | Literacy. Reading ability was assessed using the Wide Range Achievement Test _ 3 (WRAT-3: Wilkinson, 1993). This test requires pronunciation of increasingly complex vocabulary words. Results indicate level of Reading ability expressed as both a standard score and a grade level equivalent. This test can be useful for those persons in the lower ranges of verbal IQ (Johnstone et al., 1996). Since this study was not originally designed to test the effects of health literacy, measures such as the Test of Functional Health Literacy in Adults (TOFHLA) and the Rapid Estimate of Adult Literacy in Medicine (REALM) were not used. However, the WRAT-3 has been reported to be highly correlated with these other health literacy measures [Berkman et al., 2004]. | Methods: justification for measure
Lee S-YD | 2009 | Health literacy, social support, and health status among older adults | None
Clarke C | 2005 | Emergency department discharge instructions comprehension and compliance study | None
Bennett IM | 2009 | The contribution of health literacy to disparities in self- rated health status and preventive health behaviors in older adults | 1, 7, 9 | Significant differences in health status and preventive care utilization among older adults are well documented [5–9]. Particularly troubling are disparities in the use and delivery of immunizations and cancer screening related to race/ethnicity and educational attainment [6–12]. It is commonly thought that health literacy (the ability to use health information from any source to make appropriate health decisions) is an important contributor to these disparities [13,14]. Despite calls for research in this area, there has been little effort to assess formally the contribution of health literacy to disparities in health [3,15,16]. The only study that has addressed this question directly was limited to members of a single regional insurance carrier. 16 In addition, limitations in the screening instruments widely used to estimate health literacy undermine the importance of previous findings. These brief instruments are convenient for large studies that primarily aim to assess health outcomes [17–20]. Rather than measuring health literacy skills directly, these instruments estimate reading skills in the health context [13,20,21]. That is, they have limited ability to assess the functional capacity of an adult to use printed and written health related materials to perform a range of health- related tasks, a critical component of health literacy [15,21,22]. Methods: Potentially confounding demographic variables were identified a priori through a review of the literature on literacy and health in older adults. Demographic variables were age, sex, income, nativity (US born), and marital status [7–12,13]. 9: Although these instruments have been crucial in building an evidence base for the link between literacy and health outcomes, additional research using more-rigorous measures of health literacy are needed to confirm previous studies and solidify this developing field [22–25]. | Introduction: supports problem statement; state of the science Methods: justification of methods Discussions: supports future research based on current study
Pandit AU | 2009 | Education, literacy, and health: Mediating effects on hypertension knowledge and control | None
Hironaka LK | 2009 | Caregiver health literacy and adherence to a daily multi-vitamin with iron regimen in infants | 10 | It has been hypothesized that the relationship between health literacy and medication adherence may mediate the effect on specific health outcomes. However, several adult studies assessing the relationship between health literacy and adherence have produced varied results [3–9]. Some studies suggest worse adherence among individuals with limited health literacy [9]; others report no association [7] or even better adherence [4]. | Introduction: state of the science
Kandula NR | 2009 | The relationship between health literacy and knowledge improvement after a multimedia type 2 diabetes education program | None
von Wagner C | 2009 | Health literacy and self-efficacy for participating in colorectal cancer screening: The role of information processing | 2 | The associations between health literacy and the outcome variables in this study therefore seem to contradict previous suggestions of a threshold effect where only low literacy (at the 6th grade level or below) poses a substantial problem for the enactment of health behaviors [13,29–32]. Instead, our findings may indicate that even subtle differences between adults with adequate health literacy may make an appreciable difference to important variables underpinning information processing, such as information-seeking and the effort involved in reading health education materials. As such, the findings support efforts to expand the focus of health literacy research beyond at-risk populations. | Discussion: places findings in context
Rudd RE | 2009 | A randomized controlled trial of an intervention to reduce low literacy barriers in inflammatory arthritis management | 1 | Health materials are complex and currently well over 800 peer-reviewed studies indicate a mismatch between the reading demands of these materials and the literacy skills of U.S. adults [5]. This mismatch between demands and skills has serious implications [6]. Poor literacy skills have been associated with unfavorable health outcomes for a number of chronic diseases such as diabetes, asthma, HIV, and heart disease [7]. Arthritis studies have contributed to this body of literature indicating, for example, that patients with rheumatoid arthritis who had not completed high school showed poorer clinical status than patients who had and that low formal education was a predictor of premature mortality for arthritis patients over a ten-year period [8,9]. | Introduction: supports problem statement
Bickmore TW | 2009 | Using computer agents to explain medical documents to patients with low health literacy | None
Shone LP | 2009 | The role of parent health literacy among urban children with persistent asthma | 11 | Our results differ from those of DeWalt and Pignone, who found that limited parent HL was associated with worse asthma care and outcomes [8]. However this is likely explained by differences in the range of asthma severity in the two studies. DeWalt and Pignone included children with a broad range of severity, from mild to severe, whereas our study included only children with persistent asthma.
Nitri DW | 2009 | Transformative learning intervention: effect on functional health literacy and diabetes knowledge in older African Americans | None
Sheridan SL | 2003 | A randomized comparison of patients’ understanding of number needed to treat and other common risk reduction formats | None
Schillinger D | 2009 | Effects of self-management support on structure, process, and outcomes among vulnerable patients with diabetes: a three-arm practical clinical trial | None
DeWalt DA | 2009 | Goal setting in diabetes self-management: Taking the baby steps to success | None
Wallace AS | 2009 | Literacy-appropriate educational materials and brief counseling improve diabetes self-management | 6 | The results of our intervention are consistent with other studies suggesting that goal setting is feasible and effective in vulnerable populations [26–28], and that disease-related education can improve self-management for those with low-literacy [29,30]. In addition, the health-related psychological and behavioral changes resulting from our brief intervention are comparable to other interventions incorporating much more intensive strategies. | Co-authored by DeWalt
Bosworth HB | 2009 | Two self-management interventions to improve hypertension control: a randomized trial | 2 | Health literacy was evaluated as a dichotomous variable with low literacy defined as The Rapid Estimate of Adult Literacy in Medicine (REALM) [19] score 0–60 (<9th grade level) and adequate literacy defined as REALM score 61–66 (≥9th grade level) [20]. Body mass index were obtained from patients’ medical records. | Methods: justification for measures
Kang EY | 2009 | Informed consent recall and comprehension in orthodontics: traditional vs improved readability and processability methods | None
Bryant MD | 2009 | Multimedia version of a standard medical questionnaire improves patient understanding across all literacy levels | None
Kim SH | 2009 | Health literacy and functional health status in Korean older adults | 2 | Introduction: As for the factors associated with health status in older adults, many researchers have identified problems associated with health literacy. Health literacy is defined as ‘the cognitive and social skills, which determine the motivation and ability of individuals to gain access to, understand and use information in ways that promote and maintain good health’(World Health Organization 2004). In research conducted mostly in the US, limited health literacy has been reported to have an adverse effect on health outcomes, such as the use of preventive services (Davis et al. 2001, Scott et al. 2002), adherence to medical instructions [Dewalt et al. 2004, Wolf et al. 2007) and self-management skills (Schillinger et al. 2002]. Methods: A general linear model was used to test for differences in chronic conditions and the health status between the groups while adjusting for covariates (age, education and monthly income). Models were run with and without the variable of education included as a covariate to present a conservative estimate of the effect of health literacy on health status as health literacy and education are very closely associated [Dewalt et al. 2004]. Data were analysed using SPSS Version 12Æ0 (SPSS Inc., Chicago, IL, USA). Discussion: After removing education as a covariate, the magnitude of the difference between low and high literacy groups on health status was even larger: In addition to higher activity limitations and lower subjective health, individuals with low health literacy had even lower levels of physical function and higher levels of pain. Thus, the analyses with and without including education as a covariate in this study helps to rule out the possibility of misestimating the independent relationship between health literacy and health status from under- and over-adjustment [Dewalt et al. 2004]. | Introduction: state of the science Methods: justifies analysis Discussion: places findings in context
Greene J | 2009 | Medicaid consumers and informed decisionmaking | None
Lokker N | 2009 | Parental misinterpretations of over-the-counter pediatric cough and cold medication labels | 2 | Many parents may have difficulty understanding the indications and appropriate dosing of OTC medications. In 2003, the National Assessment of Adult Literacy found that 90 million Americans have basic or below basic literacy skills, and 110 million people have basic or poor quantitative skills [22]. Low-literacy skills are associated with worse understanding of medication labels, worse knowledge of one’s disease, and worse clinical outcomes [23–33]. The role of quantitative skills, or numeracy, has been less studied [34,35], but one recent study found that low numeracy was associated with poorer understanding of food labels [36]. Little is known about caregivers’ ability to choose and dose medications appropriately for their infants and young children [37]. | Introduction: supports problem statement
Volandes AE | 2009 | Video decision support tool for advance care planning in dementia: randomised controlled trial | None
Osborn CY | 2009 | Diabetes numeracy: an overlooked factor in understanding racial disparities in glycemic control | None
Sobel RM | 2009 | Asthma 1-2-3: a low literacy multimedia tool to educate African American adults about asthma | None
Gatti ME | 2009 | Relationships between beliefs about medications and adherence | None
Galesi M | 2009 | Using icon arrays to communicate medical risks: overcoming low numeracy | None
Galesi M | 2009 | Natural frequencies help older adults and people with low numeracy to evaluate medical screening tests | None
Donelle L | 2008 | Health literacy and numeracy: key factors in cancer risk comprehension | None
Jay M | 2009 | A randomized trial of a brief multimedia intervention to improve comprehension of food labels | None
Waldrop-Valverde D | 2009 | Gender differences in medication management capacity in HIV infection: The role of health literacy and numeracy | 1 | As in previous research (Davis et al. 2006; Kripalani et al. 2006; Wolf et al. 2007), the present study also found a significant relationship between health literacy for verbal information and understanding of medication instructions. The ability to accurately read, understand and draw conclusions from verbal information is critically important for effective medication management. In a summary report developed by the Agency for Healthcare Research and Quality (AHRQ) [Berkman et al. 2004], a limited number of interventions to address low health literacy were identified. All of the studies attempted to improve presentation and understanding of verbal material and were largely successful. However, as results from the present study illustrate, further research to determine the mix of abilities required to be successful in the patient role are needed so that the essential skills for particular behaviors can be identified and intervened. | Discussion: supports research recommendations for future research
Garcia-Retamero R | 2010 | Who profits from visual aids: overcoming challenges in people’s understanding of risks [corrected] | None
Yin HS | 2010 | Parents’ medication administration errors: role of dosing instruments and health literacy | 4, 11 | [Both listed as references, but neither is cited in the article.]
Gazmararian J | 2010 | Effect of a pharmacy-based health literacy intervention and patient characteristics on medication refill adherence in an urban health system | None
Mbaezue N | 2010 | The impact of health literacy on self-monitoring of blood glucose in patients with diabetes receiving care in an inner-city hospital | None
Cordasco KM | 2009 | A low-literacy medication education tool for safety-net hospital patients | 5 | Studies have shown an association between lower levels of health literacy and less medication knowledge and adherence [4–7]. Health literacy, “the ability to read, understand, and act upon health information” [8] is associated with multiple outcome disparities [9].
Garcia-Retamero R | 2009 | Communicating treatment risk reduction to people with low numeracy skills: a cross-cultural comparison | None
Bailey SC | 2009 | Predictors of misunderstanding pediatric liquid medication instructions | None
Yin HS | 2009 | The health literacy of parents in the United States: a nationally representative study | 1 | Increased national attention has been focused on the issue of health literacy, because a growing body of evidence has linked limited literacy skills to poorer health knowledge, worse health behaviors, and increased health care costs [1–4]. With an estimated $106 to $238 billion dollars in annual health care costs attributable to limited health literacy, 5 organizations including the Agency for Healthcare Research and Quality, the Institute of Medicine, the Joint Commission, the American Medical Association, and the American Academy of Pediatrics have begun to prioritize health literacy as a key quality and patient-safety issue [1,2,4,6,7]. | Introduction: supports problem statement
Coffman MJ | 2010 | Demands of immigration, health literacy, and depression in recent Latino immigrants | 2 | Ethnicity is associated with low health literacy; as many as 62% of Latinos have low or marginal health literacy, even when tested in Spanish (Paasche-Orlow, Parker, Gazmararian, Nielson-Bohlman, & Rudd, 2005). Prior research has found relationships between low health literacy and inadequate preventive health care use (Scott, Gazmararian, Williams, & Baker, 2002) and poor health outcomes [Dewalt, Berkman, Sheridan, Lohr, & Pignone, 2004]. Several studies have also found a relationship between low health literacy and depressive symptoms. Though explained by their worse health status, one study found that elders with low health literacy were more than twice as likely to report symptoms of depression (Gazmararian, Baker, Parker, & Blazer, 2000). Finally, a study that included Latina women who spoke Spanish, were recent immigrants, and were pregnant (Bennett, Culhane, McCollum, Mathew, & Elo, 2007) found that those with inadequate health literacy had more than two times the risk of reporting depression symptoms. | Introduction: state of science
Mancuso JM | 2010 | Impact of health literacy and patient trust on glycemic control in an urban USA population | 12 | To date, there is limited research available that combines health literacy and patient trust as variables that influence glycemic control. One study (n = 268) was found that combined health literacy and patient trust with self-efficacy and patient involvement in decision-making to determine their influence on glycemic control. No relationship between health literacy, patient trust, self-efficacy, and patient involvement was found. In addition, no relationship was found between health literacy or patient trust and glycemic control [DeWalt et al., 2007]. The significant positive correlation found between health literacy and diabetes knowledge was consistent with the previously discussed framework and literature [DeWalt et al., 2007; Powell et al., 2007].
Johnson VR | 2010 | Does social support help limited-literacy patients with medication adherence?: A mixed methods study of patients in the pharmacy intervention for limited literacy (PILL) study | 1, 5 | Introduction: Another factor contributing to medication adherence is health literacy—the ability to understand and use health information to make important decisions affecting one’s health [26–34]. Previous studies have shown that limited-literacy patients have difficulty correctly identifying medicines [35,36] and understanding how to take medicine [4,28,37,38]. They are reluctant to ask providers questions, possibly because they are ashamed to admit they do not understand [39–41]. In interviews and focus groups, patients said they had not told anyone about their reading difficulties [39], not even their spouses or children [40,42]. They also said they had never brought anyone with them to the hospital to help them read materials or understand what they were reading [39]. About 77 million Americans lack the literacy skills needed to take perform tasks such as determining what time they should take prescription medication as it relates to food [43]. Most at risk are people with low incomes, immigrants who do not speak English well, people >65 years of age, those with chronic conditions or mental illnesses, and individuals in racial/ethnic minority populations [27,28]. People with limited literacy are more likely to be hospitalized and visit emergency rooms than those with stronger literacy skills [27]. Discussion: Patients in both of the limited-literacy focus groups said relatives began helping them after they were hospitalized for medication overdoses or interactions. These problems might have been associated with difficulty reading and understanding medication instructions. This explanation is in line with findings that limited-literacy patients are more likely to have difficulty understanding how to take their medicines [4,28,37,38] and are more likely to visit emergency rooms and hospitals than those with stronger literacy skills [27]. | Introduction: supports problem statement Discussion: places findings in context
Murphy DA | 2010 | Health literacy and antiretroviral adherence among HIV-infected adolescents | None
Shieh C | 2009 | Health literacy and its association with the use of information sources with barriers to information seeking in clinic-based pregnant women | None
Osborn CY | 2010 | Health literacy in the context of HIV treatment: Introducing the Brief Estimate of Health Knowledge and Action (BEHKA)—HIV version | None
Sharif I | 2010 | Relationship between child health literacy and body mass index in overweight children | 11 | Better health literacy, an individual’s ability to read and interpret health information needed to make health decisions [1], has been correlated with better health outcomes in adults [2–36]. While some investigators have begun to explore the relationship between parental health literacy and child health outcomes [37,38], no recent studies have evaluated the contribution of children’s own health literacy to health outcomes.

Table D3 Key to References for omega-3 update search

| Citation
1 | Balk E, Chung M, Lichtenstein A, et al. Effects of omega-3 fatty acids on cardiovascular risk factors and intermediate markers of cardiovascular disease. Evidence report/technology assessment no 93 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). AHRQ publication no 04-E010-2. Rockville, Md: Agency for Healthcare Research and Quality; 2004. http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=hserta&part=A136037. Accessed November 6, 2009.
2 | Balk EM, Lichtenstein AH, Chung M, Kupelnick B, Chew P, Lau J. Effects of omega-3 fatty acids on serum markers of cardiovascular disease risk factors: a systematic review. Atherosclerosis 2006;189:19–30.
3 | Wang C, Harris WS, Chung M, et al. n–3 Fatty acids from fish or fish-oil supplements, but not alpha-linolenic acid, benefit cardiovascular disease outcomes in primary- and secondary-prevention studies: a systematic review. Am J Clin Nutr 2006;84:5–17.

Table D4 Citation frequency and purpose for omega-3 update search

First Author | Year | Title | References | Text | Purpose of citation
Dodin | 2008 | Flaxseed on cardiovascular disease markers in healthy menopausal women: a randomized, double-blind, placebo-controlled trial | None
Maki | 2008 | Effects of Adding Prescription Omega-3 Acid Ethyl Esters to Simvastatin (20 mg/day) on Lipids and Lipoprotein Particles in Men and Women With Mixed Dyslipidemia | None
Gajos | 2010 | Effects of Polyunsaturated Omega-3 Fatty Acids on Responsiveness to Dual Antiplatelet Therapy in Patients Undergoing Percutaneous Coronary Intervention | None
Bays | 2010 | Effects of Prescription Omega-3-Acid Ethyl Esters on Non–High-Density Lipoprotein Cholesterol When Coadministered With Escalating Doses of Atorvastatin | 1 | From a safety and tolerability standpoint, the coadministration of P-OM3, 4 g/d, with atorvastatin was generally well tolerated. Although mild glucose elevations were observed in this trial, this finding is consistent with those from other randomized clinical trials involving omega-3 fatty acid administration [17,18]. Otherwise, no unexpected tolerability or safety concerns were found in this study. | Discussion: places findings in context
Hartweg | 2007 | Meta-analysis of the effects of n-3 polyunsaturated fatty acids on haematological and thrombogenic factors in type 2 diabetes | 1 | We are not aware of other systematic reviews including only randomised control trials that have evaluated the effect of n-3 PUFA on established and emerging cardiovascular risk factors in type 2 diabetes. A recent review included patients with diabetes as part of a high-risk-group analysis, but also included non-randomised control trials [41]. There are three previous systematic reviews evaluating the effect of n-3 PUFA on cardiovascular events, lipid and glycaemic markers in type 2 diabetes [42–44], which found n-3 PUFA reduced triacylglycerol, modestly increased LDL-cholesterol, and had no significant effect on fasting glucose, HbA1c, or total cholesterol and HDL-cholesterol. However, unlike previous systematic reviews, we also assessed the effects on other established and emerging cardiovascular risk factors. | Discussion: clarifies that study fills gap
Ramel | 2008 | Beneficial effects of long-chain n-3 fatty acids included in an energy-restricted diet on insulin resistance in overweight and obese European young adults | None
Roth | 2009 | Prescription Omega-3 Fatty Acid as an Adjunct to Fenofibrate Therapy in Hypertriglyceridemic Subjects | None
Sjoberg | 2010 | Dose-dependent increases in heart rate variability and arterial compliance in overweight and obese adults with DHA-rich fish oil supplementation | None
Ninio | 2008 | Docosahexaenoic acid-rich fish oil improves heart rate variability and heart rate responses to exercise in overweight adults | None
Carney | 2010 | Effect of Omega-3 Fatty Acids on Heart Rate Variability in Depressed Patients With Coronary Heart Disease | None
Kelley | 2009 | DHA Supplementation Decreases Serum C-Reactive Protein and Other Markers of Inflammation in Hypertriglyceridemic Men1–3 | None
Davidson | 2007 | Efficacy and Tolerability of Adding Prescription Omega-3 Fatty Acids 4 g/d to Simvastatin 40 mg/d in Hypertriglyceridemic Patients: An 8-Week, Randomized, Double-Blind, Placebo-Controlled Study | 1 | Fasting blood glucose was significantly increased with P-OM3 compared with placebo (P = 0.002). Two previous meta-analyses reported that elevations in glucose after omega-3 fatty acid supplementation were not accompanied by increases in HbAlc [26, 27]. The duration of the present study was too short to allow meaningful assessment of HbAlc, but a post hoc evaluation of fructosamine levels, which respond more rapidly to changes in blood glucose levels than HbAlc, found no significant difference in the change from baseline in fructosamine levels between the P-OM3 and placebo groups. | Discussion: places findings in context
Lindqvist | 2007 | Herring (Clupea harengus) supplemented diet influences risk factors for CVD in overweight subjects | None
Engstron | 2003 | Effects of Scandinavian caviar paste enriched with a stable fish oil on plasma phospholipid fatty acids and lipid peroxidation | None
O’Keefe | 2006 | Effects of Omega-3 Fatty Acids on Resting Heart Rate, Heart Rate Recovery After Exercise, and Heart Rate Variability in Men With Healed Myocardial Infarctions and Depressed Ejection Fractions | None
Morgan | 2006 | Effects of Dietary Omega-3 Fatty Acid Supplementation on Endothelium-Dependent Vasodilation in Patients With Chronic Heart Failure | None
Ambring | 2006 | Mediterranean-inspired diet lowers the ratio of serum phospholipid n_6 to n_3 fatty acids, the number of leukocytes and platelets, and vascular endothelial growth factor in healthy subjects1–3 | None
Chan | 2003 | Randomized controlled trial of the effect of n–3 fatty acid supplementation on the metabolism of apolipoprotein B-100 and chylomicron remnants in men with visceral obesity1–3 | Before report released
Ma | 2010 | Effects of Walnut Consumption on Endothelial Function in Type 2 Diabetic Subjects | None
Rajaram | 2009 | Walnuts and fatty fish influence different serum lipid fractions in normal to mildly hyperlipidemic individuals: a randomized controlled study1–4 | 2 | Unlike walnuts, fatty fish did not lower cholesterol but, as shown by others (15, 26, 27), had a cholesterol-raising effect. Of the 2 long-chain n23 PUFA found in fish, DHA is reported to be more potent in raising cholesterol and this may be due to greater conversion of DHA-enriched VLDL to LDL cholesterol or down regulation of LDL cholesterol receptor [26, 28].We found that the hypercholesterolemic effect of DHA was magnified in those subjects who had increased baseline cholesterol levels. The increase in LDL cholesterol from the fish diet may not suggest an increased risk of CVD as this may be counteracted by a shift of LDL cholesterol toward a larger, less atherogenic LDL cholesterol particle [29]. | Discussion: places findings in context
Mostad | 2006 | Effects of n_3 fatty acids in subjects with type 2 diabetes: reduction of insulin sensitivity and time-dependent alteration from carbohydrate to fat oxidation | None
Kabir | 2007 | Treatment for 2 mo with n_3 polyunsaturated fatty acids reduces adiposity and some atherogenic factors but does not improve insulin sensitivity in women with type 2 diabetes: a randomized controlled study1–4 | None
Brady | 2004 | Increased n_6 polyunsaturated fatty acids do not attenuate the effects of long-chain n_3 polyunsaturated fatty acids on insulin sensitivity or triacylglycerol reduction in Indian Asians1–3 | None
Stark | 2004 | Differential eicosapentaenoic acid elevations and altered cardiovascular disease risk factor responses after supplementation with docosahexaenoic acid in postmenopausal women receiving and not receiving hormone replacement therapy1–3 | Could be before the release of the report
Stirban | 2010 | Effects of n–3 fatty acids on macro- and microvascular function in subjects with type 2 diabetes mellitus1–3 | None
Kelley | 2007 | Docosahexaenoic acid supplementation improves fasting and postprandial lipid profiles in hypertriglyceridemic men1_4 | None
Patenaude | 2009 | Bioavailability of a-linolenic acid from flaxseed diets as a function of the age of the subject | None
Goyens | 2006 | Effects of alpha-linolenic acid versus those of EPA/DHA on cardiovascular risk markers in healthy elderly subjects | None
Olano-Martin | 2010 | Contribution of apolipoprotein E genotype and docosahexaenoic acid to the LDL-cholesterol response to fish oil | 2 | However, high dose EPA +DHA intakes have also been associated with a highly heterogeneous LDL-cholesterol (LDLC) raising effect which may negate the cardioprotective benefits in susceptible individuals [5–7]. In the 13 studies (n = 6969 participants) reviewed by Balk et al. [5], mean LDL-C responses to fish oil ranged from −3% to +14%, observations which are comparable to the mean 5% and 11% increases in LDL-C reported in normolipidaemic (fasting triglycerides (TG) <2.0mmol/l) and hypertriglyceridaemic (fasting TG >2mmol/l) participants, respectively, in the Harris analysis [6]. | Introduction: lays out state of the science
Tuleta | 2009 | Antiplatelet effects of n-3 polyunsaturated fatty acids compared with aspirin: A pilot study with whole-blood aggregometry | None
Wang | 2008 | Fish oil supplementation improves large arterial elasticity in overweight hypertensive patients | None
Pedersen | 2003 | Influence of fish oil supplementation on in vivo and in vitro oxidation resistance of low-density lipoprotein in type 2 diabetes | Predates report
Lara | 2007 | Benefits of salmon eating on traditional and novel vascular risk factors in young, non-obese healthy subjects | None
Chan | 2006 | Factorial study of the effect of n–3 fatty acid supplementation and atorvastatin on the kinetics of HDL apolipoproteins A-I and A-II in men with abdominal obesity1–3 | None
Rizza | 2009 | Fish oil supplementation improves endothelial function in normoglycemic offspring of patients with type 2 diabetes | None
Dyerberg | 2004 | Effects of trans- and n-3 unsaturated fatty acids on cardiovascular risk markers in healthy males. An 8 weeks dietary intervention study | May predate report
Woodman | 2003 | Effects of purified eicosapentaenoic acid and docosahexaenoic acid on platelet, fibrinolytic and vascular function in hypertensive type 2 diabetic patients | Predates report
Mita | 2007 | Eicosapentaenoic acid reduces the progression of carotid intima-media thickness in patients with type 2 diabetes | None
Hill | 2007 | Combining fish-oil supplements with regular aerobic exercise improves body composition and cardiovascular disease risk factors1–3 | None
Rallidis | 2003 | Combining fish-oil supplements with regular aerobic exercise improves body composition and cardiovascular disease risk factors1–3 | Predates report
Lee | 2006 | Effects of omega-3 polyunsaturated fatty acids on plasma indices of thrombogenesis and inflammation in patients post-myocardial infarction | None
Lovegrove | 2004 | Moderate fish-oil supplementation reverses low-platelet, long-chain n_3 polyunsaturated fatty acid status and reduces plasma triacylglycerol concentrations in British Indo-Asians1–3 | May predate report
Paschos | 2007 | Dietary supplementation with flaxseed oil lowers blood pressure in dyslipidaemic patients | None
Rallidis | 2004 | The effect of diet enriched with α-linolenic acid on soluble cellular adhesion molecules in dyslipidaemic patients | May predate report
Tuttle | 2008 | Comparison of Low-Fat Versus Mediterranean-Style Dietary Intervention After First Myocardial Infarction (from The Heart Institute of Spokane Diet Intervention and Evaluation Trial) | None
Dokholyan | 2004 | A Trial of Omega-3 Fatty Acids for Prevention of Hypertension | May predate report
Bemelmans | 2004 | Increased a-linolenic acid intake lowers C-reactive protein, but has no effect on markers of atherosclerosis | May predate report
Cazzola | 2007 | Age- and dose-dependent effects of an eicosapentaenoic acid-rich oil on cardiovascular risk factors in healthy male subjects | None
Rasmussen | 2006 | Effects of dietary saturated, monounsaturated, and n_3 fatty acids on blood pressure in healthy subjects1–3 | None
Lindman | 2004 | The effects of long-term diet and omega-3 fatty acid supplementation on coagulation factor VII and serum phospholipids with special emphasis on the R353Q polymorphism of the FVII gene | May predate report
Erkkila | 2004 | Fish intake is associated with a reduced progression of coronary artery atherosclerosis in postmenopausal women with coronary artery disease1–4 | May predate report
Maki | 2010 | Baseline Lipoprotein Lipids and Low-Density Lipoprotein Cholesterol Response to Prescription Omega-3 Acid Ethyl Ester Added to Simvastatin Therapy | None
Sanders | 2006 | Effect of varying the ratio of n_6 to n_3 fatty acids by increasing the dietary intake of α-linolenic acid, eicosapentaenoic and docosahexaenoic acid, or both on fibrinogen and clotting factors VII and XII in persons aged 45–70 y: the OPTILIP Study1_3 | None
Griffin | 2006 | Effects of altering the ratio of dietary n_6 to n_3 fatty acids on insulin sensitivity, lipoprotein size, and postprandial lipemia in men and postmenopausal women aged 45–70 y: the OPTILIP Study1–3 | None
Grundt | 2003 | Changes in tissue factor and activated factor XII following an acute myocardial infarction were uninfluenced by high doses of n-3 polyunsaturated fatty acids | Predates report
Caslake | 2008 | Effect of sex and genotype on cardiovascular biomarker response to fish oils: the FINGEN Study1–3 | 2, 3 | At intakes of _2 g EPA_DHA/d, additional cardioprotective benefits such as antithrombotic actions and a positive effect on vascular reactivity, blood pressure, plasma lipid concentrations, and lipoprotein subclass distribution have been reported [13–17]. The hypotriacylglycerolemic action of these relatively high fishoil n_3 FA intakes is well recognized; the degree of triacylglycerol (TAG) lowering is comparable to the response observed with commonly used pharmacologic treatments such as fibrates. Furthermore, as highlighted in a recent systematic review [8], data on the effects of EPA and DHA on cardiovascular disease (CVD) outcomes in different population subgroups are limited. The lipid response to fish-oil supplementation is known to be highly heterogeneous both within and between studies. In a previous study, our group [19] reported a group mean reduction of 35% in fasting TAG and an increase of 7.1% in fasting LDL cholesterol concentrations after supplementation for 6 wk with 3 g EPA DHA/d, as compared with the control oil (CO). However, these mean responses represented ranges of 114% to 61% in TAG concentrations and of 49% to 87% in LDL cholesterol concentrations in the 55 participants [19]. It is likely that factors such as health status, medication use, background diet, age, sex, baseline lipid concentrations, and genetic variability account for this highly heterogeneous blood lipid response to fish-oil intervention, but the relative effect of these factors is unknown. The ability to draw definitive conclusions from this earlier study was limited by the facts that it was conducted in subjects with an atherogenic lipoprotein phenotype and that it lacked adequate statistical power to examine genotype-phenotype associations. Therefore, in the present study, the FINGEN Study, prospective recruitment according to sex, age, and APOE genotype was used in a normolipidemic population to evaluate the effect of these factors on lipid responses to fish-oil supplementation by using EPADHA intakes that are achievable by the general population through an increase in the consumption of oily fish. | Introduction: study fills gap
Hjerkinn | 2005 | Influence of long-term intervention with dietary counseling, long chain n–3 fatty acid supplements, or both on circulating markers of endothelial activation in men with long-standing hyperlipidemia1–3 | None
Park | 2009 | Fruit, vegetable, and fish consumption and heart rate variability: the Veterans Administration Normative Aging Study1–3 | None
Niu | 2006 | Dietary long-chain n_3 fatty acids of marine origin and serum C-reactive protein concentrations are associated in a population with a diet rich in marine products1–3 | None
Djousse | 2003 | Dietary linolenic acid and carotid atherosclerosis: the National Heart, Lung, and Blood Institute Family Heart Study1–3 | Predates report
Hino | 2004 | Very long chain N-3 fatty acids intake and carotid atherosclerosis. An epidemiological study evaluated by ultrasonography | None
He | 2008 | Intakes of long-chain n–3 polyunsaturated fatty acids and fish in relation to measurements of subclinical atherosclerosis1–3 | 2 | The effects of LC n–3 PUFAs on atherosclerosis may be mediated through PUFAs’ roles in lipoprotein metabolism. In the present study, we found that fish and LC n–3 PUFA intakes were associated with lower triglyceride concentrations. LC n–3 PUFAs and nonfried fish were positively related to HDL. LCn–3 PUFAs also were inversely associated with total:HDL cholesterol. No statistically significant associations were found for LDL and total cholesterol. A recent meta-analysis of 21 randomized controlled trials summarized the effects of fish-oil supplementation on lipid values [39]. The meta-analysis suggests that fish-oil consumption significantly reduces serum triglycerides and modestly improves HDL. However, fish-oil intake increases the concentration of LDL cholesterol and has no effect on total cholesterol. It is uncertain how these combined effects of LC n–3 PUFAs on lipid values affect the development or progression of atherosclerosis. | Discussion: places findings in context
He | 2009 | Associations of Dietary Long-Chain n-3 Polyunsaturated Fatty Acids and Fish with Biomarkers of Inflammation and Endothelial Activation (From the Multi-Ethnic Study of Atherosclerosis [MESA]) | None
Ohsawa | 2008 | Dietary intake of n-3 polyunsaturated fatty acids is inversely associated with CRP levels, especially among male smokers | None
Saito | 2008 | Effects of EPA on coronary artery disease in hypercholesterolemic patients with multiple risk factors: Sub-analysis of primary prevention cases from the Japan EPA Lipid Intervention Study (JELIS) | None
Oikawa | 2009 | Suppressive effect of EPA on the incidence of coronary events in hypercholesterolemia with impaired glucose metabolism: Sub-analysis of the Japan EPA Lipid Intervention Study (JELIS) | None

Tables D3 and D4 serve similar functions as Tables D1 and D2. Table D4 lists all the articles identified as being relevant for inclusion during an update of the Effects of Omega-3 Fatty Acids on Cardiovascular Risk Factors and Intermediate Markers of Cardiovascular Disease report and provides the author, year, and title of the article. Table D3 serves as a key to understanding the codes in the column titled “References” in Table D4.