# Appendix C Potentially Relevant National Institutes of Health (NIH) Requests for Applications and Program Announcements

Table C1 Requests for Applications (RFAs) and Program Announcements since 1993 for “health literacy”

Announcement Number | Related Announc. | Issuing Organization | Release Date | Opening Date (SF424 Only) | Expiration Date | Activity Code(s) | Title
PAR-11-023 | See Related | AHRQ | 11/09/2010 | 01/16/2011 | 01/08/2014 | R21 | Patient Safety and Medical Liability Reform Planning Projects (R21)
PAR-11-024 | See Related | AHRQ | 11/09/2010 | 12/25/2010 | 01/08/2014 | R18 | Advances in Patient Safety through Simulation Research (R18)
PAR-11-025 | See Related | AHRQ | 11/09/2010 | 12/25/2010 | 01/08/2014 | R18 | Patient Safety and Medical Liability Reform Demonstration Projects (R18)
RFA-HS-11-002 | See Related | AHRQ | 11/08/2010 | n/a | 02/16/2011 | U18 | Infrastructure for Maintaining Primary Care Transformation (IMPaCT) Support for Models of Multi-sector, State-level Excellence (U18)
RFA-DK-10-009 | See Related | NIDDK | 08/24/2010 | n/a | 11/18/2010 | P30 | NIDDK Centers for Diabetes Translation Research (P30)
RFA-LM-10-001 | See Related | NLM | 05/13/2010 | 06/14/2010 | 07/15/2010 | G08 | NLM Information Resource Grants to Reduce Health Disparities (G08)
PAR-10-168 | See Related | AHRQ | 04/15/2010 | 05/16/2010 | 03/17/2014 | R03 | AHRQ Small Research Grant Program (R03)
RFA-EB-10-002 | See Related | NIBIB | 03/19/2010 | 04/20/2010 | 01/08/2011 | R43, R44 | Development and Translation of Medical Technologies that Reduce Health Disparities (SBIR [R43/R44])
PA-10-100 | See Related | NIAAA | 03/17/2010 | 05/05/2010 | 05/08/2013 | R01 | Alcohol Use Disorders: Treatment, Services Research, and Recovery (R01)
PA-10-101 | See Related | NIAAA | 03/17/2010 | 05/16/2010 | 05/08/2013 | R03 | Alcohol Use Disorders: Treatment, Services Research, and Recovery (R03)
PA-10-102 | See Related | NIAAA | 03/17/2010 | 05/16/2010 | 05/08/2013 | R21 | Alcohol Use Disorders: Treatment, Services Research, and Recovery (R21)
PAR-10-133 | See Related | OBSSR | 03/12/2010 | 05/05/2010 | 05/08/2013 | R01 | Understanding and Promoting Health Literacy (R01)
PAR-10-134 | See Related | OBSSR | 03/12/2010 | 05/16/2010 | 05/08/2013 | R03 | Understanding and Promoting Health Literacy (R03)
PAR-10-135 | See Related | OBSSR | 03/12/2010 | 05/16/2010 | 05/08/2013 | R21 | Understanding and Promoting Health Literacy (R21)
RFA-MD-10-005 | See Related | NCMHD | 03/12/2010 | 04/17/2010 | 05/18/2010 | R01 | NCMHD Advances in Health Disparities Research on Social Determinants of Health (R01)
RFA-HS-10-010 | See Related | AHRQ | 02/19/2010 | 02/28/2010 | 03/30/2010 | R01 | ARRA OS Recovery Act 2009 Limited Competition: Enhanced State Data for Analysis and Tracking of Comparative Effectiveness Impact: Improved Clinical Content and Race-Ethnicity Data (R01)
RFA-HS-10-013 | See Related | AHRQ | 02/19/2010 | 02/23/2010 | 04/08/2010 | R18 | ARRA OS Recovery Act 2009 Limited Competition: Comparative Effectiveness Delivery System Demonstration Grants (R18)
RFA-HS-10-012 | See Related | AHRQ | 02/12/2010 | 02/18/2010 | 04/01/2010 | R01 | ARRA OS Recovery Act 2009 Limited Competition: Comparative Effectiveness Delivery System Evaluation Grants (R01)
RFA-HS-10-014 | See Related | AHRQ | 02/05/2010 | 02/24/2010 | 03/25/2010 | R18 | ARRA OS: Recovery Act 2009 Limited Competition: Accelerating Implementation of Comparative Effectiveness Findings on Clinical and Delivery System Interventions by Leveraging AHRQ Networks (R18)
PA-10-089 | See Related | AHRQ | 01/21/2010 | 03/01/2010 | 01/08/2013 | R18 | Prevention and Management of Healthcare Associated Infections (R18)
RFA-HS-10-015 | See Related | AHRQ | 01/21/2010 | 02/10/2010 | 03/11/2010 | R01 | ARRA OS: Recovery Act 2009 Limited Competition: Scalable Distributed Research Networks for Comparative Effectiveness Research (R01)
RFA-HS-10-018 | See Related | AHRQ | 01/21/2010 | 02/26/2010 | 06/22/2010 | R18 | Improving Patient Safety through Simulation Research (R18)
RFA-HS-10-020 | See Related | AHRQ | 01/21/2010 | 02/28/2010 | 03/30/2010 | R01 | ARRA OS Recovery Act 2009 Limited Competition: Enhanced Registries for Quality Improvement and Comparative Effectiveness Research (R01)
RFA-HS-10-001 | See Related | AHRQ | 12/22/2009 | n/a | 01/21/2010 | R24 | Recovery Act 2009 Limited Competition: Expansion of Research Capability to Study Comparative Effectiveness in Complex Patients (R24)
RFA-HS-10-009 | See Related | AHRQ | 12/17/2009 | 12/20/2009 | 01/21/2010 | R21 | Recovery Act 2009 Limited Competition OS ARRA: Comparative Effectiveness Research to Optimize Prevention and Healthcare Management for the Complex Patient (R21)
RFA-HS-10-016 | See Related | AHRQ | 12/17/2009 | n/a | 03/26/2010 | P50 | Active Aging: Supporting Individuals and Enhancing Community-based Care through Health Information Technology (HIT) (P50)
PA-10-008 | See Related | NINR | 10/05/2009 | 01/16/2010 | 01/08/2013 | R03 | Mechanisms, Models, Measurement, and Management in Pain Research (R03)
RFA-CA-09-032 | See Related | NCI | 10/02/2009 | n/a | 12/16/2009 | U54 | Community Networks Program (CNP) Centers for Reducing Cancer Disparities through Outreach, Research and Training (U54)
RFA-HD-09-010 | See Related | NICHD | 07/24/2009 | 09/28/2009 | 12/01/2009 | R03 | Limited Competition: Addressing Health Disparities in Maternal and Child Health through Community-Based Participatory Research (R03)
RFA-MD-09-007 | See Related | NCMHD | 05/12/2009 | n/a | 07/02/2009 | P20 | Recovery Act Limited Competition: NCMHD Exploratory Centers of Excellence (P20)
RFA-MD-09-005 | See Related | NCMHD | 04/14/2009 | n/a | 06/20/2009 | P20 | NCMHD Exploratory Centers of Excellence (P20)
RFA-HS-09-001 | See Related | AHRQ | 02/20/2009 | n/a | 04/22/2009 | R24 | AHRQ Research Infrastructure Program: Phase II Limited Competition (R24)
PAR-09-092 | See Related | NICHD | 01/30/2009 | 03/01/2009 | 03/03/2011 | U13 | Academic-Community Partnership Conference Series (U13)
PAR-09-085 | See Related | AHRQ | 01/23/2009 | 02/09/2009 | 01/08/2012 | K08 | Mentored Clinical Scientist Research Career Development Award (K08)
PAR-09-086 | See Related | AHRQ | 01/23/2009 | 02/09/2009 | 01/08/2012 | K02 | Independent Scientist Award (K02)
PAR-09-087 | See Related | AHRQ | 01/23/2009 | 02/09/2009 | 01/08/2012 | K01 | Mentored Research Scientist Research Career Development Award (K01)
PA-09-070 | See Related | AHRQ | 01/02/2009 | 01/05/2009 | 01/08/2012 | R01 | AHRQ Health Services Research Projects (R01)
PA-09-071 | See Related | AHRQ | 01/02/2009 | 02/09/2009 | 01/08/2012 | R18 | AHRQ Health Services Research Demonstration and Dissemination Grants (R18)
RFA-ES-09-001 | See Related | NIEHS | 12/23/2008 | 03/01/2009 | 04/02/2009 | R21 | Research to Action: Assessing and Addressing Community Exposures to Environmental Contaminants (R21)
RFA-EB-09-001 | See Related | NIBIB | 12/16/2008 | 01/20/2009 | 01/08/2010 | R43, R44 | Development and Translation of Medical Technologies that Reduce Health Disparities (SBIR [R43/R44])
PAR-08-261 | See Related | NICHD | 09/08/2008 | 12/15/2008 | 09/16/2010 | R01 | Research on Emergency Medical Services for Children (R01)
RFA-MD-08-004 | See Related | NCMHD | 05/29/2008 | n/a | 08/01/2008 | P20 | NCMHD Exploratory Centers of Excellence (P20)
RFA-MD-08-005 | See Related | NCMHD | 05/28/2008 | n/a | 08/30/2008 | P60 | NCMHD Comprehensive Centers of Excellence (P60)
RFA-DE-08-009 | See Related | NIDCR | 12/26/2007 | 01/22/2008 | 11/15/2008 | R21 | Developing Complex Models of Oral Health Behavior (R21)
RFA-HS-08-002 | See Related | AHRQ | 11/16/2007 | 01/21/2008 | 02/22/2008 | R18 | Ambulatory Safety and Quality Program: Improving Management of Individuals with Complex Healthcare Needs through Health IT (R18)
RFA-CA-08-004 | See Related | NCI | 11/09/2007 | n/a | 02/23/2008 | P50 | Centers of Excellence in Cancer Communication Research II (CECCR II) (P50)
PA-07-391 | See Related | NINR | 06/29/2007 | 09/05/2007 | 09/08/2010 | R21 | Reducing Health Disparities Among Minority and Underserved Children (R21)
PA-07-392 | See Related | NIH | 06/29/2007 | 09/05/2007 | 09/08/2010 | R01 | Reducing Health Disparities Among Minority and Underserved Children (R01)
RFA-DE-08-008 | See Related | NIDCR | 05/03/2007 | n/a | 11/16/2007 | U54 | Centers for Research to Reduce Disparities in Oral Health (U54)
PA-07-282 | See Related | NINR | 01/08/2007 | 01/08/2007 | 01/08/2010 | R01 | Mechanisms, Models, Measurement, and Management in Pain Research (R01)
RFA-AI-07-004 | See Related | NIAID | 12/27/2006 | n/a | 03/14/2007 | U01 | Women’s Interagency HIV Study (WIHS) IV, Limited Competition (U01)
PA-07-169 | See Related | NIDCR | 12/14/2006 | 01/05/2007 | 01/08/2010 | R01 | Epidemiological and Behavioral Research in Oral Health (R01)
PA-07-151 | See Related | NIDCR | 12/12/2006 | 01/05/2007 | 01/08/2010 | R01 | Oral Health of Special Needs and Older Populations (R01)
RFA-HS-07-007 | See Related | AHRQ | 12/05/2006 | 01/15/2007 | 02/16/2007 | R18 | Ambulatory Safety and Quality: Enabling Patient-Centered Care through Health IT (R18)
PAR-07-020 | See Related | OBSSR | 11/20/2006 | 01/05/2007 | 01/26/2010 | R01 | Understanding and Promoting Health Literacy (R01)
PAR-07-018 | See Related | OBSSR | 10/27/2006 | 03/23/2007 | 01/26/2010 | R21 | Understanding and Promoting Health Literacy(R21)
PAR-07-019 | See Related | OBSSR | 10/27/2006 | 03/23/2007 | 01/26/2010 | R03 | Understanding and Promoting Health Literacy (R03)
RFA-AG-07-005 | See Related | NIA | 10/27/2006 | n/a | 01/09/2007 | P30 | Resource Centers and Coordinating Center for Minority Aging Research (RCMAR)
PA-06-542 | See Related | NINR | 08/31/2006 | 09/01/2006 | 01/08/2010 | R21 | Mechanisms, Models, Measurement, & Management in Pain Research (R21)
PA-06-543 | See Related | NINR | 08/31/2006 | 09/01/2006 | 01/08/2010 | R03 | Mechanisms, Models, Measurement, & Management in Pain Research (R03)
PA-06-544 | See Related | NINR | 08/31/2006 | n/a | 01/03/2007 | R01 | Mechanisms, Models, Measurement, & Management in Pain Research (R01)
RFA-DE-07-008 | See Related | NIDCR | 07/28/2006 | 11/19/2006 | 01/20/2007 | R21 | Health Promotion Research Directed to Improving the Oral Health of Women and Their Infants (R21)
PA-06-351 | See Related | NCI | 04/12/2006 | 05/02/2006 | 05/08/2009 | R21 | Exploratory Grants for Behavioral Research in Cancer Control (R21)
PAR-06-246 | See Related | NIDCR | 03/17/2006 | 05/02/2006 | 01/08/2008 | R21 | NIDCR Exploratory and Developmental Grants in Clinical Research (R21)
PAR-06-132 | See Related | OBSSR | 03/02/2006 | 05/02/2006 | 10/14/2006 | R03 | Understanding and Promoting Health Literacy (R03)
RFA-IP-06-008 | See Related | NIP | 02/22/2006 | n/a | 04/10/2006 | U01 | Racial/Ethnic Differences in Parental Factors Related to Children Missing Scheduled Immunization Visits
RFA-LM-06-001 | See Related | NLM | 01/12/2006 | n/a | 03/18/2006 | T15 | Institutional Grants for Research Training in Biomedical Informatics (T15)
RFA-DP-04-003 | See Related | NCCDPHP | 05/13/2005 | n/a | 06/16/2005 | U48 | Health Promotion and Disease Prevention Research Centers: Special Interest Project Competitive Supplements
RFA-CD-05-108 | See Related | OPHR | 05/02/2005 | n/a | 06/18/2005 | P01 | Centers of Excellence in Health Marketing and Health Communication
PAR-05-020 | See Related | NIDCR | 11/23/2004 | n/a | 05/02/2006 | R21 | NIDCR Exploratory and Developmental Grants in Clinical Research
PAR-04-116 | See Related | OBSSR | 06/22/2004 | n/a | 10/14/2006 | R01 | UNDERSTANDING AND PROMOTING HEALTH LITERACY (R01)
PAR-04-117 | See Related | OBSSR | 06/22/2004 | n/a | 03/02/2006 | R03 | UNDERSTANDING AND PROMOTING HEALTH LITERACY (R03)
RFA-ES-04-007 | See Related | NIEHS | 06/09/2004 | n/a | 01/08/2005 | R25 | ENVIRONMENTAL JUSTICE: PARTNERSHIPS FOR COMMUNICATION
RFA-CD-04-001 | See Related | OPHR | 04/22/2004 | n/a | 06/23/2004 | K01 | CDC PUBLIC HEALTH RESEARCH: HEALTH PROTECTION RESEARCH INITIATIVE MENTORED RESEARCH SCIENTIST DEVELOPMENT AWARD (KO1)
RFA-CD-04-002 | See Related | OPHR | 04/22/2004 | n/a | 06/23/2004 | R01 | CDC PUBLIC HEALTH RESEARCH: HEALTH PROTECTION RESEARCH INITIATIVE INVESTIGATOR INITIATED RESEARCH (R01)
PA-04-031 | See Related | NIDCR | 12/08/2003 | n/a | 11/01/2006 | R01 | ORAL HEALTH OF SPECIAL NEEDS AND OLDER POPULATIONS
PA-04-022 | See Related | NIDCR | 11/14/2003 | n/a | 11/01/2006 | R01, U01 | EPIDEMIOLOGICAL AND BEHAVIORAL RESEARCH IN ORAL HEALTH
RFA-DE-04-009 | See Related | NIDCR | 11/14/2003 | n/a | 04/15/2004 | R21 | NIDCR EXPLORATORY AND DEVELOPMENTAL GRANTS IN CLINICAL RESEARCH
PAS-03-166 | See Related | NINDS | 08/28/2003 | n/a | 07/01/2006 | R01 | REDUCING STROKE DISPARITIES THROUGH RISK FACTOR SELF-MANAGEMENT
RFA-ES-03-007 | See Related | NIEHS | 04/22/2003 | n/a | 10/18/2003 | | ENVIRONMENTAL JUSTICE: PARTNERSHIPS FOR COMMUNICATION
RFA-ES-03-002 | See Related | NIEHS | 10/28/2002 | n/a | 01/15/2003 | | ENVIRONMENTAL JUSTICE: PARTNERSHIPS FOR COMMUNICATION
RFA-DE-02-004 | See Related | NIDCR | 01/11/2002 | n/a | 04/19/2002 | | PILOT GRANTS FOR RESEARCH TO PREVENT OR REDUCE ORAL HEALTH DISPARITIES
RFA-DE-02-005 | See Related | NIDCR | 01/11/2002 | n/a | 04/19/2002 | | PLANNING GRANTS FOR RESEARCH TO PREVENT OR REDUCE ORAL HEALTH DISPARITIES
RFA-GM-02-001 | See Related | NIGMS | 08/24/2001 | n/a | 12/13/2001 | | NATIVE AMERICAN RESEARCH CENTERS FOR HEALTH
RFA-DC-02-001 | See Related | NIDCD | 07/24/2001 | n/a | 10/11/2001 | | PROMOTION AND DISEASE PREVENTION: HEALTH COMMUNICATION, DEVELOPMENT, AND DISSEMINATION
RFA-GM-00-007 | See Related | NIGMS | 08/21/2000 | n/a | 12/13/2000 | | NATIVE AMERICAN RESEARCH CENTERS FOR HEALTH
RFA-DC-00-003 | See Related | NIDCD | 07/31/2000 | n/a | 10/12/2000 | | PROMOTION AND DISEASE PREVENTION: HEALTH COMMUNICATION, DEVELOPMENT, AND DISSEMINATION
RFA-HS-00-003 | See Related | AHRQ | 10/20/1999 | n/a | 01/22/2000 | | UNDERSTANDING AND ELIMINATING MINORITY HEALTH DISPARITIES
RFA-DE-99-003 | See Related | NIDCR | 09/30/1999 | n/a | 11/16/2000 | | CENTERS FOR RESEARCH TO REDUCE ORAL HEALTH DISPARITIES
RFA-ES-99-005 | See Related | NIEHS | 04/21/1999 | n/a | 07/15/1999 | | ENVIRONMENTAL JUSTICE: PARTNERSHIPS FOR COMMUNICATION
RFA-ES-96-002 | See Related | NIEHS | 09/22/1995 | n/a | 12/23/1995 | | ENVIRONMENTAL JUSTICE: PARTNERSHIPS FOR COMMUNICATION
RFA-ES-94-005 | See Related | NIEHS | 01/07/1994 | n/a | 04/02/1994 | | ENVIRONMENTAL EQUITY: PARTNERSHIPS FOR COMMUNICATION

Table C2 Requests for Applications (RFAs) and Program Announcements since 1993 for “omega 3,” “fish oil,” “n-3 fatty acids,” and “omega-3 fatty acids”

Announcement Number | Related Announc. | Issuing Organization | Release Date | Opening Date (SF424 Only) | Expiration Date | Activity Code(s) | Title
RFA-HD-12-105 | See Related | NICHD | 08/30/2010 | 11/21/2010 | 12/22/2010 | R03 | The Role of Human- Animal Interaction in Child Health and Development (R03)
PA-10-239 | See Related | NIAAA | 07/30/2010 | 09/05/2010 | 09/08/2013 | R01 | Nutrition and Alcohol- Related Health Outcomes (R01)
PA-10-240 | See Related | NIAAA | 07/30/2010 | 09/16/2010 | 09/08/2013 | R03 | Nutrition and Alcohol- Related Health Outcomes (R03)
PA-10-241 | See Related | NIAAA | 07/30/2010 | 09/16/2010 | 09/08/2013 | R21 | Nutrition and Alcohol- Related Health Outcomes (R21)
PA-10-088 | See Related | NCI | 03/17/2010 | 05/16/2010 | 05/08/2013 | R21 | Exploratory Cancer Prevention Studies Involving Molecular Targets for Bioactive Food Components (R21)
RFA-HD-10-008 | See Related | NICHD | 01/29/2010 | n/a | 06/02/2010 | U10 | Eunice Kennedy Shriver NICHD Maternal Fetal Medicine Units Network (U10)
RFA-HD-09-030 | See Related | NICHD | 08/11/2009 | 10/19/2009 | 11/20/2009 | R03 | The Role of Human- Animal Interaction in Child Health and Development (R03)
RFA-HD-09-031 | See Related | NICHD | 08/11/2009 | 10/19/2009 | 11/20/2009 | R01 | The Role of Human- Animal Interaction in Child Health and Development (R01)
RFA-HL-10-001 | See Related | NHLBI | 10/30/2008 | n/a | 05/29/2009 | P20 | Cardiac Translational Research Implementation Program (C-TRIP) (P20)
PA-08-210 | See Related | NCI | 07/18/2008 | 09/05/2008 | 09/08/2011 | R01 | Diet-Induced Changes in Inflammation as Determinants of Colon Cancer (R01)
PA-08-211 | See Related | NCI | 07/18/2008 | 09/16/2008 | 09/08/2011 | R21 | Diet-Induced Changes in Inflammation as Determinants of Colon Cancer (R21)
PA-08-030 | See Related | NCI | 11/26/2007 | 01/05/2008 | 01/08/2011 | R01 | Exfoliated Cells, Bioactive Food Components, and Cancer (R01)
PA-08-031 | See Related | NCI | 11/26/2007 | 01/16/2008 | 01/08/2011 | R21 | Exfoliated Cells, Bioactive Food Components, and Cancer (R21)
PA-07-403 | See Related | NIAAA | 07/16/2007 | 09/05/2007 | 09/08/2010 | R01 | Nutrition and Alcohol- Related Health Outcomes (R01)
PA-07-404 | See Related | NIAAA | 07/16/2007 | 09/16/2007 | 09/08/2010 | R03 | Nutrition and Alcohol- Related Health Outcomes (R03)
PA-07-405 | See Related | NIAAA | 07/16/2007 | 09/16/2007 | 09/08/2010 | R21 | Nutrition and Alcohol- Related Health Outcomes (R21)
PA-07-362 | See Related | NCI | 04/23/2007 | 05/16/2007 | 03/17/2010 | R21 | Exploratory Cancer Prevention Studies Involving Molecular Targets for Bioactive Food Components (R21)
PA-07-207 | See Related | NCI | 12/19/2006 | 01/05/2007 | 01/08/2008 | R01 | Exfoliated Cells, Bioactive Food Components, and Cancer (R01)
PA-07-186 | See Related | NCI | 12/18/2006 | 01/05/2007 | 09/08/2008 | R01 | Diet-Induced Changes in Inflammation as Determinants of Colon Cancer (R01)
PA-07-120 | See Related | NIDA | 12/08/2006 | 01/05/2007 | 05/08/2008 | R01 | Complementary and Alternative Medicine for Substance and Alcohol Related Disorders (R01)
PA-06-424 | See Related | NIDA | 05/19/2006 | 05/19/2006 | 05/08/2008 | R03 | Complementary and Alternative Medicine for Substance and Alcohol Related Disorders (R03)
PA-06-425 | See Related | NIDA | 05/19/2006 | 05/19/2006 | 05/08/2008 | R21 | Complementary and Alternative Medicine for Substance and Alcohol Related Disorders (R21)
PA-06-359 | See Related | NCI | 04/13/2006 | 05/02/2006 | 01/08/2008 | R21 | Exfoliated Cells, Bioactive Food Components, and Cancer (R21)
PA-06-360 | See Related | NCI | 04/13/2006 | 05/02/2006 | 01/08/2008 | R03 | Exfoliated Cells, Bioactive Food Components, and Cancer (R03)
PA-06-283 | See Related | NCI | 03/28/2006 | 05/02/2006 | 09/08/2008 | R21 | Diet-Induced Changes in Inflammation as Determinants of Colon Cancer (R21)
PA-05-125 | See Related | NCI | 06/20/2005 | n/a | 01/03/2007 | R01, R21 | Diet-Induced Changes in Inflammation as Determinants of Colon Cancer
PA-05-097 | See Related | NIDA | 04/26/2005 | n/a | 01/03/2007 | R01, R03, R21 | Complementary and Alternative Medicine for Substance and Alcohol Related Disorders
PA-04-114 | See Related | NCI | 06/18/2004 | n/a | 01/03/2007 | R01, R03, R21 | Exfoliated Cells, Bioactive Food Components, and Cancer
RFA-CA-01-015 | See Related | NCI | 09/20/2000 | n/a | 02/15/2001 | | Planning Grant for Collaborations on Nutritional Modulation of Genetic Pathways Leading to Cancer
RFA-HL-98-005 | See Related | NHLBI | 12/05/1997 | n/a | 03/18/1998 | | Origins of Asthma in Early Life
RFA-CA-95-010 | See Related | NCI | 04/14/1995 | n/a | 07/13/1995 | | Human Metabolic Studies of Modification of Dietary Fatty Acid Intake for Prevention of Dietary Fatty Acid Intake for Prevention of Breast, Prostate, and Colon Cancer
RFA-HL-94-013 | See Related | NHLBI | 04/01/1994 | n/a | 09/16/1994 | | Specialized Centers of Research in Hemostatic and Thrombotic Disease
PA-93-103 | See Related | NIDDK | 08/20/1993 | n/a | 08/20/1996 | | Nutrition in Cystic Fibrosis
PA-93-065 | See Related | NIDDK | 03/19/1993 | n/a | 03/19/1996 | | Nutrient Antioxidants, Cellular Metabolism and Function