# Appendix B Sources Searched for Assessment of Impact of an EPC Report

Table B1 Sources Searched for Assessment of Impact of an EPC Report

Source | URL | Date of Last Search | Yield | Ease of Use^*^ | Import Function? | Search Strategy | Dates of Coverage
FOR PUBLISHED LITERATURE
CINAHL | http://www.ebscohost.com/cinahl/ | 2/9/2010 | 209 | Satisfactory | Yes | “community-based participatory research” OR CBPR, limited to publication years 2004–2010; 85 were duplicates with other databases, 124 were unique and imported. | 1982-present
Cochrane Library | http://www.cochrane.org/ | 2/9/2010 | 4 | Satisfactory | Yes | “community-based participatory research” OR CBPR, limited to publication years 2004–2010; 3 duplicates, 1 imported. | varies
Google Scholar | http://scholar.google.com/ | 5-Feb-10 | 187 | Satisfactory | Yes/1 at a time | Viswanathan “Community-Based Participatory Research: Assessing the Evidence” | Not available
ISI Web of Science | http://apps.isiknowledge.com/ | 2/9/2010 | 404 | Satisfactory | Yes | “community-based participatory research” OR CBPR; 25 were duplicates with PubMed/final total 379 | Science Citation Index Expanded (SCI- EXPANDED)--1955-present Social Sciences Citation Index (SSCI)--1956-present Arts & Humanities Citation Index (A&HCI)--1975- present
PubMed/Medline | http://www.ncbi.nlm.nih.gov/pubmed/ | 2/5/2010 | 597 | Satisfactory | Yes | “Related Articles” link to the Viswanathan report in PubMed | 1950-present
FOR ONGOING STUDIES
AHRQ grants database | http://www.gold.ahrq.gov/ | 2/9/2010 | 5 | Difficult/No Boolean searching | No | “community-based participatory research”; CBPR | 1998-present
ClinicalTrials.gov | http://clinicaltrials.gov | 2/9/2010 | 10 | Satisfactory | No | “community-based participatory research” OR CBPR | Unavailable/Updated continuously
CMS Web site | http://www.cms.hhs.gov/ | 2/9/2010 | 0 | Satisfactory | No | “community-based participatory research” OR CBPR | Unavailable
CMS Active Projects Report | http://www.cms.hhs.gov/ActiveProjectReports/ | 2/9/1010 | 0 | Satisfactory | No | “community-based participatory research” OR CBPR | Fiscal Year 2009
Commonwealth Fund | http://www.commonwealthfund.org/Grants-and-Programs/Search-Grants.aspx | 2/10/2010 | 0 | Satisfactory | No | “community-based participatory research” OR CBPR | 1995–2010
Department of Veterans Affairs | http://www.va.gov/ | 2/9/1010 | 1 | Satisfactory | No | “community-based participatory research” OR CBPR | Unavailable
The Foundation Directory Platinum Online (UNC has subscription) | http://fconline.foundationcenter.org/ | 2/11/2010 | 18 | Satisfactory | No | “community-based participatory research” OR CBPR | 2003-present
HRSA grants | http://www.hrsa.gov/grants/ | 2/10/2010 | 0 | Difficult | No | “+community-based +participatory +research OR +CBPR” | 2010
HSRProj | http://wwwcf.nlm.nih.gov/hsr_project/home_proj.cfm | 2/10/2010 | 86 | Satisfactory | Yes | “community-based participatory research” OR CBPR | Projects are listed until 4 years after each project's end date
Kaiser Family Foundation | http://www.kaisernetwork.org/gsa/kffadvanced.jsp | 2/10/2010 | 0 | Satisfactory | No | “community-based participatory research” as a phrase, OR CBPR
NIH RePORTER (previously CRISP) | http://projectreporter.nih.gov/reporter.cfm | 2/10/1010 | 189 | Difficult | No | “Community-Based Participatory Research” “Assessing the Evidence” OR CBPR - limited to Fiscal Years: Active projects | 1986-present
Rural Health Research Gateway | http://www.ruralhealthresearch.org/ | 2/10/2010 | 0 | Satisfactory | No | “community-based participatory research” OR CBPR | 2006-present
RWJF grants database online | http://www.rwjf.org/grants/pg.jsp | 2/10/2010 | 49 | Satisfactory | No | “Community-Based Participatory Research” OR CBPR | Within the last 5 years
SPIN (InfoEd International) (UNC has subscription) | http://www.infoed.org/new_spin/spinmain.asp | 2/10/2010 | 19 | Satisfactory | No | phrase search: community-based participatory research (32); CBPR (6). There may be overlap | Unavailable/Updated continuously
FOR SOLICITATIONS
FedBizOpps (Federal Business Opportunities) (click “Find Opportunities”) | https://www.fbo.gov | 2/9/1010 | 0 | Difficult | No | “community-based participatory research” OR CBPR | Past year
Grants.gov | http://www.grants.gov | 5-Feb-10 | 0 | Difficult/Phrase searching unavailable | No | “community-based participatory research” OR CBPR | Unavailable
HHS Grants Forecast | https://extranet.acf.hhs.gov/hhsgrantsforecast/ | 10-Feb-10 | 0 | Difficult | No | “community-based participatory research” OR CBPR | 2009-September 2011 (estimated posting)
INPUT
National Institutes of Health [NIH] Guide for Grants and Contracts | http://grants.nih.gov/grants/guide/ | 10-Feb-10 | 32 | Difficult/Phra se searching unavailable | No | Community-Based Participatory Research (20); CBPR (12) some overlap; 5 copied, 1 cited the Viswanathan report. | 1993-present (Historical files available 1970–1992)
FOR BOTH ONGOING STUDIES AND SOLICITATIONS
Google, limited to .gov sites | http://www.google.com | 5-Feb-10 | 12+ | Satisfactory | No | Viswanathan “Community-Based Participatory Research: Assessing the Evidence” | Not applicable

* Ease of Use is rated as Satisfactory or Difficult. Sources with a Satisfactory rating recognized phrase searching and Boolean connectors, or other helpful search instructions were provided. In addition, the search “worked,” providing results containing the search terms. Those sources with a Difficult rating did not recognize phrase searching and/or Boolean connectors, and/or there were no search instructions, and/or the search results did not contain the search terms.