# Appendix A Case Study Identification

## Identification of Potential Case Studies

We sent each EPC director a memo from us asking for nominations. Specifically, we asked for nominations of systematic reviews from EPC-II and EPC-III known to have had impact on future research. We offered some examples:

The report was commissioned by a research agency for the express purpose of identifying future research needs.

The report, although not commissioned for the purpose, influenced the development of RFAs and RFPs.

The report influenced the field through its results and gaps analysis and was the catalyst for investigator-initiated funding.

The report influenced the development of guidelines or policy, which in turn, resulted in future research funding.

We received responses from 7 of 14 EPC directors after two reminders. Two EPC directors could not identify EPC reviews that had impact. A third identified an instance of reverse impact, that is, the EPC review was commissioned as a result of ongoing work for another agency. The remaining four EPCs nominated a total of 16 reviews, ranging from 1 to 7. Table A1 presents all nominations provided by EPC directors.

Table A1 Nominations for potential case studies

Nominator EPC | Topic | Date of publication | Type of impact | Cited impact | Notes
Tufts | Vitamin D35 | 2009 | Practice guidelines | Institute of Medicine Dietary Reference Intake revision on vitamin D | Likely too recent to be able to measure impact
Tufts | Breastfeeding36 | 2007 | Practice guidelines | Office of Women’s Health recommendations
RTI-UNC | Second-generation antidepressants37 | 2007 | Investigator- initiated research and external funding | Additional studies funded by DERP, AHRQ, and others | Attribution likely difficult: part of ongoing research debate; RTI-UNC review
RAND | Health information technology38 | 2006 | Investigator- initiated funding | Additional work by David Blumenthal and the ONC, HIE federal policies | Research volume influenced by stimulus funding
Tufts | Soy39 | 2005 | External funding | National Center for Complementary and Alternative Medicine/NIH Office of Dietary Supplements future research
RTI-UNC | Episiotomy40 | 2005 | Practice guidelines | American College of Obstetrics and Gynecology guidelines | RTI-UNC review
RAND | Surgical treatment of obesity41 | 2004 | Practice guidelines | Clinical practice guidelines by the American College of Physicians
Tufts | Omega-3 fatty acids10,11 | 2004 | External funding | National Heart, Lung and BIood Institute future research
RTI-UNC | Community-based participatory research21 | 2004 | Investigator- initiated research and external funding | Cited in requests for applications and proposals | Research methods, atypical of EPC reviews; part of ongoing research methods development; RTI- UNC review
RTI-UNC | Health literacy9 | 2004 | Investigator- initiated research, practice guidelines | IOM report, additional funding for investigators, cited in RFAs | RTI-UNC review
RAND | Ephedra42 | 2003 | Change in policy | Used at the justification to withdraw ephedra from the market | EPC 1: attribution issues
Tufts | Neonatal hyperbilirubinemia43 | 2003 | Practice guidelines | American Academy of Pediatrics guidelines | EPC 1: attribution issues
McMaster | Dissemination of cancer control interventions44 | 2003 | NR | NR | EPC 1, attribution issues
RTI-UNC | Systems to rate the strength of evidence45 | 2002 | Investigator- initiated research? | Cited in numerous methodological papers | EPC 1; attribution issues; part of ongoing methods development; RTI- UNC review
RTI-UNC | Prostate cancer screening46,47 | 2002 | External funding | CDC funding on communication of PSA messages | EPC 1: attribution issues; RTI-UNC review
RTI-UNC | Preterm labor48 | 2000 | External funding | Follow-on report funded by AHRQ | EPC 1: attribution issues; RTI-UNC review

Entries in the table appear in reverse chronological order; the most recent reports are listed first. We evaluated each nomination for concerns regarding measurement or attribution of impact and the likelihood for potential conflict of interest (Notes column in Table A1). Under-attribution of impact is a risk for more recent reports. Overattribution is a likely risk of for older reports that are often routinely cited in ongoing research as background material. Key informants may have recall issues as well. Other external factors include the volume of other ongoing research and sharp increases in funding: in these instances, a likely risk is over-attribution of impact. We also identify the RTI-UNC EPC reports clearly because evaluating these reports may present a conflict of interest for this investigator (MV is first author on 2 of 7 RTI-UNC EPC reports in the list below). Reports that we judged to be the best choices for case study are shown in bold. We identify four likely choices other than the RTI-UNC reports: two reports that influenced external funding (soy and omega-3 fatty acids) by the Tufts EPC and two reports that led to clinical practice guidelines (surgical treatment of obesity and breastfeeding) by the RAND (Southern California) and Tufts EPCs, respectively.