# Acknowledgments

The RTI International—University of North Carolina at Chapel Hill Evidence-based Practice Center (RTI-UNC EPC) would like to thank our peer reviewers who gave generously of their time. We are grateful for advice and review from Drs. Stephanie Chang and Yen-Pin Chiang from AHRQ through the course of the project. We also express our gratitude to RTI staff Loraine Monroe, our EPC Publications Specialist, and Jennifer Drolet, editor.